# References

Abelson MB, Mandel E, Paradis A, et al The effect of hyaluronidase on akinesia during cataract surgery Ophthalmic Surg 1989 May 20(5):325 6 2726146
Agrawal K, Saxena RC, Nath R, et al. Local anesthesia by peribulbar block for cataract extraction in an eye relief camp. A double-masked, randomized controlled trial. Online J Curr Clin Trials. 1993 Mar19. Doc. No. 40.
Agrawal V, Athanikar NS Single injection, low volume periocular anesthesia in 1,000 cases J Cataract Refract Surg 1994 Jan 20(1):61 3 8133482
Ali-Melkkila T, Virkkila M, Leino K, et al Regional anaesthesia for cataract surgery: Comparison of three techniques Br J Ophthalmol 1993 Dec 77(12):771 3 8110669 504652
Anderson CJ Subconjunctival anesthesia in cataract surgery J Cataract Refract Surg 1995 Jan 21(1):103 5 7722890
Anderson NJ, Nath R, Anderson J Comparison of preservative-free bupivacaine vs lidocaine for intracameral anesthesia: A randomized clinical trial and in vitro analysis Am J Ophthalmol 1999 127(4):393 402 10218691
Athanikar NS, Agrawal VB One point low volume peribulbar anaesthesia versus retrobulbar anaesthesia. A prospective clinical trial Indian J Ophthalmol 1991 Apr 39(2):48 9 1916978
Bell RW, Butt ZA Warming lidocaine reduces the pain of injection during peribulbar local anaesthesia for cataract surgery Br J Ophthalmol 1995 Nov 79(11):1015 7 8534645 505319
Bjornstrom L, Hansen A, Otland N, et al Peribulbar anaesthesia. A clinical evaluation of two different anaesthetic mixtures Acta Ophthalmol (Copenh) 1994 Dec 72(6):712 4 358319 7747581
Boezaart AP, Berry RA, Laubscher JJ, et al Evaluation of anxiolysis and pain associated with combined peri- and retrobulbar eye block for cataract surgery J Clin Anesth 1998 May 10(3):204 10 9603590
Briggs MC, Beck SA, Esakowitz L Sub-Tenon's versus peribulbar anaesthesia for cataract surgery Eye 1997 11(Pt 5):639 43 9474310
Buttery R, Wise G Conal anaesthesia: A new approach to retrobulbar anaesthesia Aust N Z J Ophthalmol 1989 Feb 17(1):63 9 2765283
Carino NS, Slomovic AR, Chung F, et al Topical tetracaine versus topical tetracaine plus intracameral lidocaine for cataract surgery J Cataract Refract Surg 1998 Dec 24(12):1602 8 9850898
Cataract in adults: Management of functional impairment. Clinical Practice Guideline, No. 4. Rockville (MD): U.S. Department of Health and Human Services, Agency for Health Care Policy and Research. 1993 Feb. AHCPR Publication No. 93-0542.
Charlson ME, Pompei P, Ales KL, et al. A new method for classifying prognostic comorbidity in longitudinal studies: Development and validation. J Chron Dis. 1987;40:373-83. [pmid: 3558716].
Chittenden HB, Meacock WR, Govan JA Topical anaesthesia with oxybuprocaine versus sub-Tenon's infiltration with 2 percent lidocaine for small incision cataract surgery Br J Ophthalmol 1997 Apr 81(4):288 90 9215056 1722170
Chung F, Cheng DC, Seyone C, et al A randomized comparison of midazolam and diazepam injectable emulsion in cataract surgery Can J Anaesth 1990 Jul 37(5):528 33 2197003
Coley S, Jones GW, Lassey D, et al A comparison of the effects of alfentanil/droperidol or fentanyl/droperidol on intra-ocular pressure Anaesthesia 1990 Jun 45(6):477 80 2382805
Corboy JM, Jiang X Postanesthetic hypotropia: A unique syndrome in left eyes J Cataract Refract Surg 1997 Nov 23(9):1394 8 9423914
Crandall AS, Zabriskie NA, Patel BC, et al A comparison of patient comfort during cataract surgery with topical anesthesia versus topical anesthesia and intracameral lidocaine Ophthalmology 1999 Jan 106(1):60 6 9917782
Cruise CJ, Chung F, Yogendran S, et al Music increases satisfaction in elderly outpatients undergoing cataract surgery Can J Anaesth 1997 Jan 44(1):43 8 8988823
Cugini U, Lanzetta P, Nadbath P, et al Sedation with ketamine during cataract surgery J Cataract Refract Surg 1997 Jun 23(5):784 6 9278803
Davis DB, Mandel MR Posterior peribulbar anesthesia: An alternative to retrobulbar anesthesia J Cataract Refract Surg 1986 Mar 12(2):182 4 3701637
Davis PL, O'Connor JP Peribulbar block for cataract surgery: A prospective double-blind study of two local anesthetics Can J Ophthalmol 1989 Jun 24(4):155 8 2743201
Demirok A, Simsek S, Cinal A, et al Peribulbar anesthesia: One versus two injections Ophthalmic Surg Lasers 1997 Dec 28(12):998 1001 9427987
Dinsmore SC Drop, then decide approach to topical anesthesia J Cataract Refract Surg 1995 Nov 21(6):666 71 8551444
Dinsmore SC Approaching a 100 percent success rate using topical anesthesia with mild intravenous sedation in phacoemulsification procedures Ophthalmic Surg Lasers 1996 Nov 27(11):935 8 8938802
Dopfmer UR, Maloney DG, Gaynor PA, et al Prilocaine 3 percent is superior to a mixture of bupivacaine and lidocaine for peribulbar anaesthesia Br J Anaesth 1996 Jan 76(1):77 80 8672385
Edge KR, McClarty CP, Krige SJ, et al Comparison of an extraconal block with a retrobulbar-facial block combination for ocular surgery. A safe alternative technique to the combination of retrobulbar block and facial nerve block S Afr J Surg 1995 Sep 33(3):117 9 8607053
el-Bassiouny O, el-Taher EM, el-Din ABD Alfentanil/promazine versus meperidine/promazine as a sedative regimens during local analgesia for cataract operation Doc Ophthalmol 1992 82(3):201 10 1303855
Ellingsson A, Aasved H Etidocaine and lidocaine in ophthalmic surgery. Short communication Acta Ophthalmol (Copenh) 1979 Aug 57(4):543 6 358319 393055
Feibel RM, Custer PL, Gordon MO Postcataract ptosis. A randomized, double-masked comparison of peribulbar and retrobulbar anesthesia Ophthalmology 1993 May 100(5):660 5 8493007
Filos KS, Patroni O, Goudas LC, et al A dose-response study of orally administered clonidine as premedication in the elderly: Evaluating hemodynamic safety Anesth Analg 1993 Dec 77(6):1185 92 8250311
Fukasaku H, Marron JA Pinpoint anesthesia: A new approach to local ocular anesthesia J Cataract Refract Surg 1994 Jul 20(4):468 71 7932140
Furuta M, Toriumi T, Kashiwagi K, et al Limbal anesthesia for cataract surgery Ophthalmic Surg 1990 Jan 21(1):22 5 2325991
Garbutt JC, West SL, Carey TS, et al Pharmacological treatment of alcohol dependence. A review of the evidence JAMA 1999 281(14):1318 25 10208148
Garcia A, Loureiro F, Limao A, et al. Preservative-free lidocaine 1 percent anterior chamber irrigation as an adjunct to topical anesthesia. J Cataract Refract Surg. 1998;24:403-6. [pmid: 9580374].
Gilbert J, Holt JE, Johnston J, et al Intravenous sedation for cataract surgery Anaesthesia 1987 Oct 42(10):1063 9 3688387
Gillart T, Bazin JE, Deret C, et al Effect of injection pressure on the success rate of peribulbar block Anaesthesia 1996 Aug 51(8):779 82 8795325
Gillart T, Bazin JE, Montetagaud M, et al The effects of volume and speed of injection in peribulbar anaesthesia Anaesthesia 1998 May 53(5):486 91 9659024
Gills JP, Cherchio M, Raanan MG Unpreserved lidocaine to control discomfort during cataract surgery using topical anesthesia J Cataract Refract Surg 1997 May 23(4):545 50 9209989
Guise PA Single quadrant sub-Tenon's block. Evaluation of a new local anaesthetic technique for eye surgery Anaesth Intensive Care 1996 Apr 24(2):241 4 9133200
Gutman H, Sinskey RM, Cain W A comparison of lidocaine and etidocaine in retrobulbar anesthesia for cataract surgery J Am Intraocul Implant Soc 1979 Apr 5(2):120 2 479003
Hamilton R, Claoue C Topical anesthesia: Proxymetacaine versus amethocaine for clear corneal phacoemulsification J Cataract Refract Surg 1998 Oct 24(10):1382 4 9795856
Hamilton RC, Gimbel HV, Strunin L Regional anaesthesia for 12,000 cataract extraction and intraocular lens implantation procedures Can J Anaesth 1988 Nov 35(6):615 23 3203455
Henderson TR, Franks W Peribulbar anaesthesia for cataract surgery: Prilocaine versus lidocaine and bupivacaine Eye 1996 10(Pt 4):497 500 8944106
Hendrick SW, Rosenberg MK, Lebenbom-Mansour MH Efficacy and safety of single injection peribulbar block performed by anesthesiologists prior to cataract surgery J Clin Anesth 1997 Jun 9(4):285 8 9195350
Herrick IA, Gelb AW, Nichols B, et al Patient-controlled Propofol sedation for elderly patients: Safety and patient attitude toward control Can J Anaesth 1996 Oct 43(10):1014 8 8896852
Hinshaw KD, Fiscella R, Sugar J Preparation of pH-adjusted local anesthetics Ophthalmic Surg 1995 May 26(3):194 9 7651682
Hodgkins PR, Teye-Botchway L, Morrell AJ, et al Neuroleptanalgesia and extracapsular cataract extraction Br J Ophthalmol 1992 Mar 76(3):153 6 1540558 504193
Hosal BM, Tekeli O, Gursel E Eyelid malpositions after cataract surgery Eur J Ophthalmol 1998 Jan 8(1):12 5 9590589
House PH, Hollands RH, Schulzer M Choice of anesthetic agents for peribulbar anesthesia J Cataract Refract Surg 1991 Jan 17(1):80 3 2005563
Huha T, Ala-Kokko TI, Salomaki T, et al. Clinical efficacy and pharmacokinetics of 1 percent ropivacaine and 0.75 percent bupivacaine in peribulbar anesthesia for cataract surgery. Anaesthesia. 1999;54:137-41. [pmid: 10215708].
Ibrahim WS, Savino PJ Preoperative sedation in cataract surgery: An evaluation of two regimens Ann Ophthalmol 1974 Apr 6(4):387 92 4821370
Johansen J, Kjeldgard M, Corydon L Retrobulbar anaesthesia. A clinical evaluation of four different anaesthetic mixtures Acta Ophthalmol (Copenh) 1993 Dec 71(6):787 90 358319 8154254
John T Simplified anesthesia technique for scleral tunnel phacoemulsification J Cataract Refract Surg 1998 Dec 24(12):1562 5 9850890
Johnston RL, Whitefield LA, Giralt J, et al Topical versus peribulbar anesthesia, without sedation, for clear corneal phacoemulsification J Cataract Refract Surg 1998 Mar 24(3):407 10 9559479
Jolliffe DM, Abdel-Khalek MN, Norton AC A comparison of topical anaesthesia and retrobulbar block for cataract surgery Eye 1997 11(Pt 6):858 62 9537146
Joyce PW, Sunderraj P, Villada J, et al A comparison of amethocaine cream with lidocaine-prilocaine cream (EMLA) for reducing pain during retrobulbar injection Eye 1994 8(Pt 4):465 6 7821475
Kaplan LJ, Jaffe NS, Clayman HM Ptosis and cataract surgery. A multivariant computer analysis of a prospective study Ophthalmology 1985 Feb 92(2):237 42 3982804
Kapran Z, Uyar M, Eltutar K, et al One quadrant sub-Tenon's capsule anesthesia in anterior segment surgery Eur J Ophthalmol 1996 Apr 6(2):131 6 8823584
Karhunen U, Orko R Nausea and vomiting after local anesthesia for cataract extraction in elderly female patients -- effect of droperidol premedication Ophthalmic Surg 1981 Nov 12(11):810 2 7322457
Katz J, Feldman MA, Bass EB, et al. Injectable versus topical anesthesia for cataract surgery: Patient perceptions of pain and side effects. Ophthalmology. 2000;107:2054-60. [pmid: 11054331].
Kershner RM Topical anesthesia for small incision self-sealing cataract surgery. A prospective evaluation of the first 100 patients J Cataract Refract Surg 1993 Mar 19(2):290 2 8487176
Khalil SN, Howard G, Mankarious R, et al Alfentanil decreases the excitatory phenomena of sodium methohexital J Clin Anesth 1998 Sep 10(6):469 73 9793810
Khoo BK, Lim TH, Yong V Sub-Tenon's versus retrobulbar anesthesia for cataract surgery Ophthalmic Surg Lasers 1996 Sep 27(9):773 7 8878196
Khurana AK, Sachdeva RK, Gombar KK, et al Evaluation of subconjunctival anaesthesia vs peribulbar anaesthesia in cataract surgery Acta Ophthalmol (Copenh) 1994 Dec 72(6):727 30 358319 7747584
Kishore K, Agarwal HC, Sood NN, et al Evaluation of peribulbar anesthesia in eye camps Ophthalmic Surg 1990 Aug 21(8):566 70 2234806
Koch PS Anterior chamber irrigation with unpreserved lidocaine 1 percent for anesthesia during cataract surgery J Cataract Refract Surg 1997 May 23(4):551 4 9209990
Kollarits CR, Jaweed S, Kollarits FJ Comparison of pain, motility, and preoperative sedation in cataract phacoemulsification patients receiving peribulbar or sub-Tenon's anesthesia Ophthalmic Surg Lasers 1998 Jun 29(6):462 5 9640566
Kost M, Emerson D Propofol-fentanyl versus midazolam-fentanyl: A comparative study of local sedation techniques for cataract surgery CRNA:The Clinical Forum for Nurse Anesthetists 1992 Feb 3(1):7 15 1477688
Kothari K, Shah J, Shah M, et al Combined topical peribulbar anesthesia for cataract surgery J Cataract Refract Surg 1998 Dec 24(12):1658 60 9850908
Krause M, Weindler J, Ruprecht KW. Does warming of anesthetic solutions improve analgesia and akinesia in retrobulbar anesthesia?. Ophthalmology. 1997;104:429-32. [pmid: 9082268].
Krohn J, Hovding G, Seland JH, et al Retrobulbar anesthesia with and without adrenaline in extracapsular cataract surgery. A prospective, randomized, double-blind study Acta Ophthalmol Scand 1995 Feb 73(1):56 60 7627761
Krohn J, Seland JH, Hovding G, et al Retrobulbar anesthesia with and without hyaluronidase in extracapsular cataract surgery. A prospective, randomized, double-blind study Acta Ophthalmol (Copenh) 1993 Dec 71(6):791 5 358319 8154255
Kumar A, Bose S, Bhattacharya A, et al Oral clonidine premedication for elderly patients undergoing intraocular surgery Acta Anaesthesiol Scand 1992 Feb 36(2):159 64 1549937
Kumar A, Tandon OP, Bhattacharya A, et al Recovery from pre-operative sedation with clonidine -- brain stem auditory evoked response Anaesthesia 1994 Jun 49(6):533 7 8017601
Lewis P, Hamilton RC, Brant R, et al Comparison of plain with pH-adjusted bupivacaine with hyaluronidase for peribulbar block Can J Anaesth 1992 Jul 39(6):555 8 1643678
Loots JH, Koorts AS, Venter JA Peribulbar anesthesia. A prospective statistical analysis of the efficacy and predictability of bupivacaine and a lidocaine/bupivacaine mixture J Cataract Refract Surg 1993 Jan 19(1):72 6 8426327
Maclean H, Burton T, Murray A Patient comfort during cataract surgery with modified topical and peribulbar anesthesia J Cataract Refract Surg 1997 Mar 23(2):277 83 9113582
Manners TD, Burton RL Randomized trial of topical versus sub-Tenon's local anaesthesia for small-incision cataract surgery Eye 1996 10(Pt 3):367 70 8796164
Masket S, Gokmen F Efficacy and safety of intracameral lidocaine as a supplement to topical anesthesia J Cataract Refract Surg 1998 Jul 24(7):956 60 9682117
McNamara RL, Bass EB, Miller MR, et al Management of New Onset Atrial Fibrillation. Evidence Report/Technology Assessment No.12. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-97-0006.) AHRQ Publication No. 01-E026. Rockville (MD): Agency for Healthcare Research and Quality. 2001 ERTA 12
Michelson G, Naujoks B O2 administration by a nasal probe improves respiration in cataract surgery after retrobulbar anesthesia Ophthalmic Surg 1991 Oct 22(10):615 8 1961623
Mindel JS Value of hyaluronidase in ocular surgical akinesia Am J Ophthalmol 1978 May 85(5 Pt 1):643 6 350052
Mjahed K, el Harrar N, Hamdani M, et al Lidocaine-clonidine retrobulbar block for cataract surgery in the elderly Reg Anesth 1996 Nov 21(6):569 75 8956395
Morsman CD, Holden R The effects of adrenaline, hyaluronidase and age on peribulbar anaesthesia Eye 1992 6(Pt 3):290 2 1446762
Muller FO, Claasen JP, Schall R, et al The efficacy of two bupivacaine hydrochloride injection products S Afr Med J 1996 Jun 86(6):667 9 8764423
Murdoch IE Peribulbar versus retrobulbar anaesthesia Eye 1990 4(Pt 3):445 9 2209907
Nathan N, Benrhaiem M, Lotfi H, et al The role of hyaluronidase on lidocaine and bupivacaine pharmacokinetics after peribulbar blockade Anesth Analg 1996 May 82(5):1060 4 8610868
Nielsen PJ Immediate visual capability after cataract surgery: Topical versus retrobulbar anesthesia J Cataract Refract Surg 1995 May 21(3):302 4 7674167
Nielsen PJ, Allerod CW Evaluation of local anesthesia techniques for small incision cataract surgery J Cataract Refract Surg 1998 Aug 24(8):1136 44 9719976
Nolan J, Aziz M, Ahmad M, et al Local anesthesia in cataract surgery -- a comparison of different methods Yen Ko Hsueh Pao 1993 Mar 9(1):21 2 8253178
Norregaard JC, Schein OD, Bellan L, et al. International variation in anesthesia care during cataract surgery. Results from the International Cataract Surgery Outcomes Study. Arch Ophthalmol. 1997;115:1304-8. [pmid: 9338678].
Oikkonen M Melperon premedication for cataract surgery. A comparison with diazepam Acta Anaesthesiol Scand 1994 Apr 38(3):211 3 7912875
Oikkonen M, Heine H, Salminen U, et al Dixyrazine premedication for cataract surgery. A comparison with diazepam Acta Anaesthesiol Scand 1994 Apr 38(3):214 7 7912876
Oikkonen M., Reinikainen P. Silent myocardial ischaemia in connection with cataract surgery: Effect of prophylactic oxygenation. Cardiol Elderly. 1996;4:151-5.
Ortiz M, Blanco D, Serra J, et al Peribulbar anaesthesia: The role of local anaesthetic volumes and Thiomucase in motor block and intraocular pressure Eur J Anaesthesiol 1995 Nov 12(6):603 7 8665884
Pac-Soo CK, Deacock S, Lockwood G, et al Patient-controlled sedation for cataract surgery using peribulbar block Br J Anaesth 1996 Sep 77(3):370 4 8949813
Pappa X, Pouliou K, Nastou H, et al EMLA prevents pain during local anesthesia for cataract surgery Acta Anaesthesiol Belg 1995 46(2):75 8 8714853
Patel BC, Burns TA, Crandall A, et al A comparison of topical and retrobulbar anesthesia for cataract surgery Ophthalmology 1996 Aug 103(8):1196 203 8764787
Patel BC, Clinch TE, Burns TA, et al Prospective evaluation of topical versus retrobulbar anesthesia: A converting surgeon's experience J Cataract Refract Surg 1998 Jun 24(6):853 60 9642600
Pecka SL, Dexter F Anesthesia providers'interventions during cataract extraction under monitored anesthesia care Journal of the American Association of Nurse Anesthetists 1997 65(4):357 60
Petersen WC, Yanoff M Subconjunctival anesthesia: An alternative to retrobulbar and peribulbar techniques Ophthalmic Surg 1991 Apr 22(4):199 201 2057181
Petitti DB. Meta-analysis, decision analysis and cost-effectiveness analysis: Methods for quantitative synthesis in medicine. New York: Oxford University Press; 1994.
Prosser DP, Rodney GE, Mian T, et al Re-evaluation of hyaluronidase in peribulbar anaesthesia Br J Ophthalmol 1996 Sep 80(9):827 30 8942381 505621
Redmond RM, Dallas NL Extracapsular cataract extraction under local anaesthesia without retrobulbar injection Br J Ophthalmol 1990 Apr 74(4):203 4 2337543 1042060
Reeves SR, Fleisher LA, Friedman DS, et al. A decision analysis of anesthesia management for cataract surgery. Am J Ophthalmol. in preparation.
Robinson K, Hinegardner P, Lansing P. Development of an optimal search strategy for the retrieval of controlled trials using PubMed. Abstr Workshops Sci Sess Int Cochrane Coll. 1998 Oct;6.
Roman S, Auclin F, Ullern M Topical versus peribulbar anesthesia in cataract surgery J Cataract Refract Surg 1996 Oct 22(8):1121 4 8915811
Roper DL, Nisbet RM Effect of hyaluronidase on the incidence of cystoid macular edema Ann Ophthalmol 1978 Dec 10(12):1673 8 367238
Ropo A, Ruusuvaara P, Paloheimo M, et al Periocular anaesthesia: Technique, effectiveness and complications with special reference to postoperative ptosis Acta Ophthalmol (Copenh) 1990 Dec 68(6):728 32 358319 2080707
Rosenberg MK, Raymond C, Bridge PD Comparison of midazolam/ketamine with methohexital for sedation during peribulbar block Anesth Analg 1995 Jul 81(1):173 4 7598251
Rosenfeld SL, Litinsky SM, Snyder DA, et al Effectiveness of monitored anesthesia care in cataract surgery Ophthalmology 1999 106(7):1256 60 10406602
Ruusuvaara P, Setala K, Pajari S, et al Comparison of etidocaine and bupivacaine + lidocaine in retrobulbar anaesthesia Acta Ophthalmol Scand 1995 Dec 73(6):563 6 9019387
Sanchez-Capuchino A, Meadows D, Morgan L Local anaesthesia for eye surgery without a facial nerve block Anaesthesia 1993 May 48(5):428 31 8317654
Sanders R, Ahmed S, Craig EW et al Comparison of catecholamine and pressor effects in peribulbar and retrobulbar anaesthesia in cataract surgery Eye 1997 11(Pt 5):644 8 9474311
Sarvela J, Nikki P Hyaluronidase improves regional ophthalmic anaesthesia with etidocaine Can J Anaesth 1992a Nov 39(9):920 4 1451220
Sarvela J, Nikki P Comparison of two needle lengths in regional ophthalmic anesthesia with etidocaine and hyaluronidase Ophthalmic Surg 1992b Nov 23(11):742 5 1484666
Sarvela J, Nikki P, Paloheimo M Orbicular muscleakinesia in regional ophthalmic anaesthesia with pH adjusted bupivacaine: Effects of hyaluronidase and epinephrine Can J Anaesth 1993 Nov 40(11):1028 33 8269562
Sarvela PJ Comparison of regional ophthalmic anesthesia produced by pH-adjusted 0. 75 percent and 0.5 percent bupivacaine and 1 percent and 1.5 percent etidocaine, all with hyaluronidase Anesth Analg 1993 Jul 77(1):131 4 8317720
Sarvela PJ, Paloheimo MP, Nikki PH Comparison of pH-adjusted bupivacaine 0. 75 percent and a mixture of bupivacaine 0.75 percent and lidocaine 2 percent, both with hyaluronidase, in day-case cataract surgery under regional anesthesia Anesth Analg 1994 Jul 79(1):35 9 8010450
Saunders DC, Sturgess DA, Pemberton CJ, et al Peribulbar and retrobulbar anesthesia with prilocaine: A comparison of two methods of local ocular anesthesia Ophthalmic Surg 1993 Dec 24(12):842 5 8115101
Schimek F, Steuhl KP, Fahle M Retrobulbar blockade of somatic, motor, and visual nerves by local anesthetics Ophthalmic Surg 1993 Mar 24(3):171 80 8483567
Schneider M, Faulborn J, Von Hochstetter AH Posterior peribulbar anesthesia for eye surgery Eur J Anesthesiol 1989 Nov 6(6):425 30
Scott RA, Jakeman CM, Perry SR, et al Peribulbar anaesthesia and needle length J R Soc Med 1995 Oct 88(10):594P 596P
Shammas HJ, Milkie M, Yeo R. Topical and subconjunctival anesthesia for phacoemulsification: prospective study. J Cataract Refract Surg. 1997;23:1577-80. [pmid: 9456419].
Shibata K, Inage K, Takayama T, et al Use of cold spray for relieving pain from local anesthetic injections in ocular surgery J Ophthalmic Nurs Technol 1993 Jan 12(1):23 30 8487314
Smith PH, Kemp P, Smith ER A comparison of retrobulbar block produced by etidocaine 1 percent and by a mixture of lidocaine 2 percent and bupivacaine 0. 75 percent Ophthalmic Surg 1987 Feb 18(2):106 10 3574862
Smith PH, Kim JW Etidocaine used for retrobulbar block: A comparison with lidocaine Ophthalmic Surg 1980 Apr 11(4):268 73 6992010
Smith PH, Smith ER A comparison of etidocaine and lidocaine for retrobulbar anesthesia Ophthalmic Surg 1983 Jul 14(7):569 74 6888837
Steinberg EP, Javitt JC, Sharkey PD, et al The content and cost of cataract surgery Arch Ophthalmol 1993 111(8):1041 9 8352686
Sunderraj P, Kirby J, Joyce PW, et al A double-masked evaluation of lidocaine-prilocaine cream (EMLA) used to alleviate the pain of retrobulbar injection Br J Ophthalmol 1991 Mar 75(3):130 2 2012777 1042288
Suzuki R, Kuroki S, Fujiwara N A comparison of blood pressure changes in phacoemulsification cataract surgery with topical and retrobulbar block local anesthesia Graefes Arch Clin Exp Ophthalmol 1997 May 235(5):277 82 9176675
Sweeney EJ, Barber K, Prosser JA A comparison of percutaneous and perconjunctival routes of administration of peri-ocular anaesthesia for day case cataract surgery Anaesthesia 1993 Apr 48(4):336 8 8494140
Thomson I Addition of hyaluronidase to lidocaine with adrenaline for retrobulbar anaesthesia in the surgery of senile cataract Br J Ophthalmol 1988 Sep 72(9):700 2 3052572 1041560
Thorburn W, Thorn-Alquist AM, Edstrom H Etidocaine in retrobulbar anaesthesia. A comparison with mepivacaine Acta Ophthalmol (Copenh) 1976 Oct 54(5):591 600 358319 790888
Tseng SH, Chen FK A randomized clinical trial of combined topical-intracameral anesthesia in cataract surgery Ophthalmology 1998 Nov 105(11):2007 11 9818597
Ursell PG, Spalton DJ The effect of solution temperature on the pain of peribulbar anesthesia Ophthalmology 1996 May 103(5):839 41 8637697
Uusitalo RJ, Maunuksela EL, Paloheimo M, et al Converting to topical anesthesia in cataract surgery J Cataract Refract Surg 1999 Mar 25(3):432 40 10079452
Vettese T, Breslin CW Retrobulbar anesthesia for cataract surgery: Comparison of bupivacaine and bupivacaine/lidocaine combinations Can J Ophthalmol 1985 Jun 20(4):131 4 4052861
Virkkila ME, Ali-Melkkila TM, Kanto JH Premedication for outpatient cataract surgery: A comparative study of intramuscular alfentanial, midazolam and placebo Acta Anaesthesiol Scand 1992 Aug 36(6):559 63 1514342
Virkkila M, Ali-Melkkila T, Kanto J, et al Dexmedetomidine as intramuscular premedication in outpatient cataract surgery. A placebo-controlled dose-ranging study Anaesthesia 1993 Jun 48(6):482 7 8100688
Virkkila M, Ali-Melkkila T, Kanto J, et al Dexmedetomidine as intramuscular premedication for day-case cataract surgery. A comparative study of dexmedetomidine, midazolam and placebo Anaesthesia 1994 Oct 49(10):853 8 7802178
Virtanen P, Huha T Pain in scleral pocket incision cataract surgery using topical and peribulbar anesthesia J Cataract Refract Surg 1998 Dec 24(12):1609 13 9850899
Waller SG, Taboada J, O'Connor P Retrobulbar anesthesia risk. Do sharp needles really perforate the eye more easily than blunt needles? Ophthalmology 1993 Apr 100(4):506 10 8479708
Weiss JL, Deichman CB A comparison of retrobulbar and periocular anesthesia for cataract surgery Arch Ophthalmol 1989 Jan 107(1):96 8 2910293
Whitsett JC, Balyeat HD, McClure B Comparison of one-injection-site peribulbar anesthesia and retrobulbar anesthesia J Cataract Refract Surg 1990 Mar 16(2):243 5 2256971
Wolf G, Lynch S, Berlin I Intraocular surgery with general anesthesia Arch Ophthalmol 1975 May 93(5):323 6 1147803
Wong DH, Koehrer E, Sutton HF, et al A modified retrobulbar block for eye surgery Can J Anaesth 1993 Jun 40(6):547 53 8403122
Wong DH, Merrick PM Intravenous sedation prior to peribulbar anaesthesia for cataract surgery in elderly patients Can J Anaesth 1996 Nov 43(11):1115 20 8922766
Yee JB, Burns TA, Mann JM, et al Propofol and alfentanil for sedation during placement of retrobulbar block for cataract surgery J Clin Anesth 1996 Dec 8(8):623 6 8982887
Yee JB, Schafer PG, Crandall AS, et al Comparison of methohexital and alfentanil on movement during placement of retrobulbar nerve block Anesth Analg 1994 Aug 79(2):320 3 7639372
Zehetmayer M, Radax U, Skorpik C, et al Topical versus peribulbar anesthesia in clear corneal cataract surgery J Cataract Refract Surg 1996 May 22(4):480 4 8733854
Zehetmayer M, Rainer G, Turnheim K, et al Topical anesthesia with pH-adjusted versus standard lidocaine 4% for clear corneal cataract surgery J Cataract Refract Surg 1997 Nov 23(9):1390 3 9423913