# Conclusions

The following discussion is organized around the strength of the evidence found in the literature for the key clinical questions that were identified. Issues relating to local anesthesia are presented first, followed by those relevant to systemic sedation.

## Conclusions Regarding Local Anesthesia Techniques

### Strong Evidence

The most thoroughly studied issue in the literature was the relative effectiveness of retrobulbar block and peribulbar block anesthesia. The evidence indicated that peribulbar and retrobulbar anesthesia produce equally good akinesia and equivalent pain control during cataract surgery. Comparative studies consistently found no differences between the two techniques. However, results reported in the many published case series using these two techniques varied tremendously. This is likely attributable to the fact that block techniques and sedating agents were not the same from study to study, surgical approaches and surgical times varied, and the measurement of outcomes was not standardized. Any or all of these may have contributed to the wide range of reported effectiveness of these two techniques in the uncontrolled studies. Sedation strategies may have influenced the results as well.

The literature also provided strong evidence that retrobulbar block is more painful upon injection than topical drops. Only in the presence of heavy sedation were these two approaches equally painless.

### Moderate Evidence

The pain felt upon administration of subconjunctival/sub-Tenon's blocks was less than that for retrobulbar block. While the differences were not large, and only mean pain scores were usually reported, the overall evidence was consistent and favored subconjunctival/sub-Tenon's block. In addition, the same three articles that reported less pain on administration of subconjunctival/sub-Tenon's block also found that pain during cataract surgery was less with subconjunctival/sub-Tenon's block than with retrobulbar block. While the number of studies involved was not large, the results were fairly consistent.

### Weak and Insufficient Evidence

#### Subconjunctival/Sub-Tenon's Studies

There was insufficient evidence in the literature to make any statements about the relative effectiveness of subconjunctival/sub-Tenon's block at producing akinesia when compared with peribulbar block or retrobulbar block. Only one study (nonrandomized) found similar pain control with subconjunctival/sub-Tenon's as with peribulbar block. However, as stated above, there was moderate evidence that subconjunctival/sub-Tenon's block produced better pain control than retrobulbar block. There was weak evidence that subconjunctival/sub-Tenon's block was less painful on application than peribulbar block. Finally, there was weak evidence that subconjunctival/sub-Tenon's block produces better pain control than topical anesthesia.

#### Anesthetic Agents

There was only weak evidence supporting different agents, and this was based largely on single trials. Etidocaine, mepivicaine, and bupivacaine all appeared to produce similar akinesia. Bupivacaine alone appeared to be as effective at producing akinesia as bupivacaine and lidocaine together. There was insufficient evidence to reach firm conclusions on the relative merits of one agent over another at producing pain control.

#### Hyaluronidase

While several studies compared hyaluronidase with placebo, few reported data on the effect of using hyaluronidase on pain control. On average, hyaluronidase appeared to produce better akinesia than placebo, but the results of studies addressing this issue were inconsistent, with several studies finding no benefit. In addition, hyaluronidase consistently took 2 to 3 minutes less to produce akinesia than in the control group, where hyaluronidase was not used, but the difference was not always statistically significant.

#### Other Approaches

Other approaches were attempted to improve the effectiveness of different block techniques. Three studies warmed the agents prior to the block, with little difference seen. The evidence is insufficient to comment on the relative benefit of this technique. Three studies also looked at increasing the pH of anesthetic agents in an effort to decrease the pain of the block and increase the effectiveness. The evidence from these studies is insufficient to draw conclusions.

The evidence suggests that the addition of intracameral nonpreserved lidocaine to topical anesthesia increases the pain control of this technique. The evidence also suggests that adequate pain control can be achieved in a high percentage of cataract surgical patients undergoing surgery with topical anesthesia, with or without the intracameral injection of an anesthetic agent. However, it appears that the degree of pain control with this technique is still less than with any of the block techniques. Surgeon-related factors, such as the time necessary to complete the surgery, may well be important variables in the success of topical anesthesia. However, surgical time was rarely reported.

### Limitations of the Literature on Local Anesthesia Techniques

We had hoped that the literature would provide useful information on the safety and effectiveness of alternative local anesthetic techniques relative to the professional training of the individual administering the local anesthesia, the setting of care, and the monitoring used. However, such information was rarely collected or presented by authors. Only 20 percent of the reported studies gave any information on surgical time, and surgical time was virtually always reported only as a mean value. Clearly, surgical time and the effectiveness of anesthesia as reported by patients are likely to be correlated. This methodologic problem, in addition to the others previously described, limits the inferences one can draw from much of the literature.

It is clear that a variety of techniques for local anesthesia (i.e., peribulbar, retrobulbar, subconjunctival/sub-Tenon's injection, and topical anesthesia) are highly safe and effective for the intraoperative management of cataract surgery. However, it is difficult, based on the published literature, to compare in a meaningful way the rates of ocular or systemic complications associated with different strategies for local anesthesia. For example, it is self-evident that ocular perforation does not occur with topical anesthesia or with sub-Tenon's anesthesia delivered with a blunt cannula, while perforation is a risk for any technique involving a needle. However, the rates of ocular perforation are sufficiently low (between 1 in 1,000 and 1 in 10,000 cases) that the outcome is rarely addressed directly. Other important outcomes, such as posterior capsular rupture, retrobulbar hemorrhage, and bradycardia, were also difficult to compare across techniques. This is not only because of their relative rarity, but perhaps more importantly, because of the wide variation in outcome definitions, surgical populations, and surgical techniques. Regarding the surgeon, many of the studies relied on the experience of individual surgeons (rather than on groups of surgeons using a standardized technique), thereby placing the representativeness of the reported data in question.

The evidence available from the literature and from the Study of Medical Testing for Cataract Surgery (see the section "Supplemental Analysis") is consistent regarding the use of topical versus injection anesthesia. Specifically, both sources indicate that while reported pain control is very good with both techniques, the rate of complete pain control is superior with injection techniques. However, intraoperative pain control is not the only consideration underlying choice or recommendation for anesthesia technique. Additional considerations might include, for example, patient anxiety, patient preferences for complications/side effects of one choice versus the other, discomfort on administration, need for supplemental intravenous sedation, and cost. Except for reporting on pain, the currently available literature is largely limited in its incorporation of the patient perspective into anesthesia strategy choice.

## Conclusions Regarding Sedation Strategies

With regard to sedation strategies, there are no specific questions for which there is sufficient evidence to justify a strong or moderate rating of the strength of evidence.

### Weak Evidence

Three studies directly compared intravenous or intramuscular sedation/anesthesia to local anesthesia alone using a placebo-controlled design. All showed a general trend toward improved patient-oriented outcomes (improved anxiety, pain relief, and patient satisfaction) with intravenous or intramuscular sedation. However, the total sample sizes were small and there were no differences in actual morbidity.

### Insufficient Evidence

There was insufficient evidence to determine if any one class of sedative/anesthetic agent was associated with improved outcome compared to another class.

Major morbidity was not reported in any trial. All of the studies were small and used different outcome measures. Many of the studies used combinations of agents rather than comparing a single sedative/anesthetic agent. Additionally, the type of local anesthesia technique differed between studies. Further research is required that uses a standard local anesthesia protocol and standard endpoints to better define the optimal sedative strategy.

### Limitations of the Literature on Sedation Technique

In summary, the published literature on sedation/anesthesia strategies for cataract surgery is not comprehensive. Most importantly, the literature is limited by (1) a lack of standardization of definition of the principal outcomes of interest and (2) a lack of evidence addressing the fundamental question of whether systemic sedation is associated with improved patient outcomes.