# Results

## Results of the Literature Search and Abstract Review

The completed searches yielded 1,857 potentially relevant citations, of which 739 were unique and subsequently included in the abstract review process. A summary of the searches completed, including the strategy used, date of search, number of citations retrieved, and number of unique citations identified, is included as Appendix K.

All 739 eligible abstracts were independently reviewed by two members of the study team to determine if they met eligibility criteria. For this process, we emphasized sensitivity rather than specificity. Disagreements between reviewers about whether an abstract or citation should be included in the review were adjudicated at a meeting of the entire study team. The abstract review phase ended on June 1, 1999. The citations identified during the hand-searching process were reviewed for eligibility. Of the 739 completed reviews of abstracts and citations, 195 (26 percent) were included in the full article review process and 544 (74 percent) were determined to be ineligible for the full article review. A summary of the results of the 739 abstract reviews may be found in Appendix L.

Of the 195 articles determined to be eligible for review, we were not able to obtain copies of three articles while the abstract review and full article abstraction were ongoing (Agrawal, Saxena, Nath et al., 1993; Krohn, Hovding, Seland et al., 1995; Schneider, Faulborn, and Von Hochstetter, 1989). Of the remaining 192 articles, 27.2 percent (51) were excluded during the quality review (Appendix M), leaving a total of 141. The reasons for exclusion and percent of articles excluded, by reason for exclusion, are listed in Appendix N. Articles were most frequently excluded because the data for cataract surgery were not reported separately from other types of ophthalmic surgery. The next most frequent reason for exclusion was that the outcomes assessed in the article were not directly relevant to the key outcomes prioritized for the evidence report (e.g., effect of injection on intraocular pressure, anesthetic agent concentration in aqueous, etc.).

### Design and Focus of the Studies

Seventy-five percent of the studies included in this literature review were randomized controlled trials. The remaining studies utilized nonrandomized designs: 13 percent of studies were clinical series of 100 patients or greater, 9 percent were nonrandomized controlled trials, 2 percent were cross-sectional studies, and 1 percent were cohort studies.

Safety of regional anesthesia was addressed in 41 percent of the included studies. Information on the comfort of regional anesthesia and effectiveness of anesthesia/sedation was included in 58 percent and 45 percent of the studies, respectively. Sedation strategies were the focus of 17 percent of studies, and 4 percent of studies focused on personnel, setting, and/or outcomes.

### Article Content Assessment

The methodology for the article content assessment was described in Chapter 2. All studies included in this literature review reported some data on regional anesthesia. Approximately one-half (48 percent) of included studies reported some data on planned sedation. All of the studies reviewed reported at least some data on the range of regional anesthesia techniques of interest to this literature review: data on retrobulbar anesthesia were reported in 51 percent of studies, peribulbar in 49 percent, topical anesthesia in 25 percent, and subconjunctival/sub-Tenon's anesthesia in 14 percent. More than half of the studies reported on the use of additional agents for local block anesthesia: 65 percent reported data on the use of hyaluronidase, 25 percent on the use of epinephrine, and 4 percent on the use of other agents.

The clinical outcomes of principal interest regarding regional anesthesia include: (1) akinesia (adequacy of control of eye movement during surgery); (2) pain associated with administration of the regional anesthesia; (3) pain experienced intraoperatively; and (4) associated complications.

Nearly one-half (47 percent) of the articles reviewed reported some data on the complications of regional anesthesia. Complications of regional anesthesia for which data were abstracted include brainstem anesthesia, posterior capsular rupture, retrobulbar hemorrhage, and ruptured globe. Factors related to regional anesthesia for which the evidence was reviewed also included mean or median operating time, surgical technique, and assessment of akinesia.

The majority of articles reporting on planned sedation included data on planned intravenous sedation (65 percent). Data on oral preoperative medications were reported in 32 percent of the articles reporting on planned sedation. Preoperative oral agents for which data were available include diazepam, lorazepam, other agents, and placebo. Medication classes used for planned intravenous sedation and for which data were available include benzodiazepines, barbiturates, analgesics, propofol, other medications, and saline placebo.

The clinical outcomes of principal interest regarding planned sedation include: (1) anxiety/pain control; (2) hemodynamics; and (3) associated complications.

Complications of sedation/anesthesia for which data were abstracted include cardioversion, conversion to general anesthesia, cardiopulmonary resuscitation, endotracheal intubation, benzodiazepine reversal, ischemic event, seizure, and ventilation with bag and mask. Only 9 percent of articles reviewed included a report of adverse medical outcomes (myocardial infarction, new or worsened congestive heart failure, ventricular arrhythmia, stroke, transient ischemic attack, and respiratory failure). Hemodynamic outcomes (treatment for hypertension, tachycardia, bradycardia, and oxygen desaturation) were reported in only 8 percent of articles.

Finally, the content assessment of each article included an indication of whether the study supported, refuted, or did not address four key statements. Each statement appears below along with the percent of studies supporting, refuting, or unable to address the question.

(1) Local and intravenous analgesia is superior, to a clinically significant degree, to local alone:

Article Content Assessment

Supports | 2.2 percent
Refutes | 0.7 percent
Does not address | 97.0 percent

(2) Use of intravenous sedation is superior, to a clinically significant degree, to not using intravenous sedation for:

a. Patient anxiety and satisfaction:
  Supports | 2.2 percent
  Refutes | 1.4 percent
  Does not address | 96.4 percent
b. Effect on patient physiology (metabolic or hemodynamic):
  Supports | 2.2 percent
  Refutes | 1.4 percent
  Does not address | 96.4 percent
c. Effect on patient outcomes:
  Supports | 0.0 percent
  Refutes | 2.9 percent
  Does not address | 97.1 percent

## Results of the Studies

### Evidence Table 1: Overall Summary of Literature on Anesthesia for Cataract Surgery

Evidence Table 1 provides an overview of the 141 studies identified as relevant to the study questions and meeting inclusion criteria. Studies are listed in three groups (those addressing local anesthesia techniques, those addressing sedation strategies, and those addressing both of these issues) and sorted by author within each group. All included studies were published between 1968 and 1999, with articles reviewed through April 1999. Forty studies were carried out in the United States, 62 studies in Europe, and 39 in other countries. One hundred twenty-two studies focused on local anesthesia techniques, either alone or in combination with sedation strategies. Of these, 86 were randomized clinical trials and 36 were noncontrolled studies. Ninety-two of the 122 studies did not report the criteria for exclusion or provided an inadequate report of the exclusion criteria. The number of surgeries studied in the randomized clinical trials addressing local anesthesia techniques ranged from 20 to 570. Case series tended to be larger, with a range from 100 to 4,000 surgeries.

From the total group of studies listed in Evidence Table 1, 60 specifically addressed the efficacy of sedation, 36 addressed complications of sedation, 18 addressed both, and the remaining studies addressed neither. Efficacy included assessment of cooperation, recall of pain, anxiety, and satisfaction. Complications included both medical outcomes and hemodynamics. Seventeen studies included intravenous benzodiazepines, 8 included intravenous barbiturates, 24 included intravenous analgesics, and 7 included intravenous propofol, with overlap between the groups. Twenty-seven studies described preoperative oral medications. Placebo controls were included in six randomized trials.

### Evidence Table 2: Summary of Interventions Reported in Literature on Anesthesia for Cataract Surgery

This table provides a detailed description of the interventions in each study, including details about the kind of regional anesthesia or sedation given, the specific agents, and supplemental techniques. Columns are provided on presence or absence of facial block, cataract surgical technique, and mean surgical time because the study team felt that these parameters were very important in determining and interpreting the effectiveness of the techniques and studies. Whether or not a lid block was given is listed because the administration of a lid block likely increases the pain associated with the delivery of anesthesia. In addition, the cataract removal technique is likely to influence the pain of the procedure (with clear cornea phacoemulsification less likely to cause pain than standard extracapsular cataract extraction requiring multiple sutures). Finally, mean surgical time is reported because patient comfort and pain control are certainly related to how long the surgery takes. This table includes 105 studies that are randomized controlled trials and 36 others. Overall, the cataract removal technique could be determined in only 38 percent of articles. Mean surgical time was reported in only 20 percent.

As this table demonstrates, retrobulbar and peribulbar techniques varied significantly. Agents studied for retrobulbar and peribulbar blocks included bupivacaine, lidocaine, etidocaine, prilocaine, ropivacaine, and mepivicaine. Agents studied for topical anesthesia included lidocaine, bupivacaine, oxybuprocaine, intracameral lidocaine, tetracaine, proparacaine, and amethocaine. Studies also varied based on the characteristics of needles used to administer the injections.

### Evidence Table 3: Methodologic Quality of Literature on Anesthesia for Cataract Surgery

This table summarizes the data on study quality. For each domain, the score is the percentage of the total possible points in that domain, ranging from 0 to 100. The overall quality score derives from study quality evaluated in five domains: representativeness of the population, bias and confounding, adequacy of the description of the treatment, outcomes assessment, and statistical analysis. We report scores in all domains as well as an overall score so that readers can form their own impression of the strengths and weaknesses of individual studies. In addition, we hope that this review will highlight issues relevant to the design of future trials. As a general consideration, it is important to keep in mind that our quality assessment of published reports is limited, by definition, to whatever is reported in the manuscript. Therefore, a limitation of using published reports to assess study design quality is that the evaluation is an assessment of both design and reporting quality.

Overall, 141 manuscripts were assessed for quality. Of these, 105 (75 percent) were controlled trials and 36 (25 percent) were uncontrolled trials or case series.

The mean value and range of scores for each domain and overall are presented in Appendix O. Scores for the bias and statistical quality scales are presented for controlled trials only. For controlled clinical trials, the mean overall score was 46 percent, with a range from 11 percent to 76 percent; 57 percent of these studies had an overall quality score of less than 50 percent. For the uncontrolled trials and case series, the mean overall score was 33 percent, with a range from 3 percent to 75 percent; 80 percent of these studies had an overall quality score of less than 50 percent.

Regarding representativeness, the mean score was 38, with a range from 0 to 100. Although a portion of this variability likely represents variability in reporting rather than true representativeness of the study population, it nevertheless makes it difficult for clinicians to know whether the results of these studies are likely to apply to the types of patients they see in their own practices. There is also significant variation in quality scores relating to bias and confounding (mean 48; range 0 to 100). The relatively low scores reflect the frequent lack of adequate masking of treatment supervisors, patients, and outcome assessors, and the absence of provision of adequate data on potentially important differences between study groups at baseline. For description of therapy, the mean score was 37, with a range from 0 to 86. Frequently, weaknesses were found in the description of ancillary medications or procedures given to each treatment group (e.g., the kind of intravenous sedation used in a study primarily evaluating regional anesthesia). For outcomes the mean was 55 percent, with a range from 0 percent to 80 percent, and for statistical quality the mean was 40 percent, with a range from 0 percent to 75 percent.

## Assessment of the Strength of the Evidence

The following section summarizes the evidence available in the literature regarding the key clinical questions that had previously been chosen. The methodology used to grade the evidence was described in Chapter 2. Wherever the question involved the direct comparison of alternative techniques (e.g., intraoperative pain control with peribulbar versus retrobulbar anesthesia), the summary of the evidence ends with a conclusion statement and an evidence grade.

### Evidence Regarding Regional Anesthesia

This section summarizes the evidence comparing various techniques of regional anesthesia regarding the outcomes of akinesia, pain, and complications. Whenever there existed published research making direct comparisons of alternative techniques, the findings are summarized and a conclusion accompanied by an evidence grade is given. Additional data on the techniques that could be abstracted from manuscripts containing relevant information (but where the techniques of interest were not directly compared) are also summarized in this section, but without the inclusion of evidence grades. Evidence grades were not applied to these summary sections because the contributing evidence was so heterogeneous that it could not be assessed in a uniform way.

The variability of the study designs and outcomes measured limits one's ability to synthesize the literature and address certain outcomes of interest. For example, one might be interested to ascertain if the characteristics (e.g., length, gauge, sharpness) of the needle used for an injection technique influenced the outcome. However, in the absence of direct comparisons, it is impossible to reach firm conclusions. Any possible effect of needle attributes is hopelessly confounded by other factors differing in each study, such as the injection technique itself, anesthetic choice, and presence/absence of sedation. This methodologic issue plagues many questions, particularly those relating to perception of pain during the block and surgery. The techniques and metrics for measuring pain varied substantially by study, and more importantly, the studies addressing pain perception varied regarding whether intravenous sedation was used. This, among other factors (variable surgical technique, operating time, etc.), is likely to have contributed significantly to the heterogeneity of the findings.

#### Evidence Table 4. Local Anesthesia: Is there a difference between peribulbar and retrobulbar anesthetic block in achieving akinesia?

Seven randomized trials directly addressed this question. Two of these studies reported the percentage of patients for whom complete akinesia was obtained (Ali-Melkkila, Virkkila, Leino et al., 1993; Athanikar and Agrawal, 1991). There was no difference between the two techniques, with complete akinesia rates of over 70 percent reported for both arms in the two studies.

Three studies reported the percentage of subjects for whom akinesia was poor. One study (Ali-Melkkila, Virkkila, Leino et al., 1993) (450 subjects, quality score 58) reported twice the rate of poor akinesia using one peribulbar technique (one injection inferotemporal and one injection superomedial) than using an alternative technique (one injection inferotemporal and one injection inferomedial). The rate was 12 percent with retrobulbar, 19 percent with the first peribulbar technique, and 11 percent with the second peribulbar technique. Another study (Murdoch, 1990) (100 subjects, quality score 44) reported a much higher rate of poor akinesia with retrobulbar (single inferotemporal injection) than with peribulbar (20 percent versus 6 percent). The third study (Wong, Koehrer, Sutton et al., 1993) (150 subjects, quality score 65) reported a very high rate of poor akinesia with a single inferotemporal retrobulbar injection (26 percent). Lower rates of poor akinesia were found for superomedial retrobulbar injection (8 percent) and peribulbar injection (10 percent).

Three other studies did not report on the percentage with complete or poor akinesia, but did compare retrobulbar and peribulbar block using mean scores for akinesia (Saunders, Sturgess, Pemberton et al., 1993; Weiss and Deichman, 1989; Whitsett, Balyeat, and McClure, 1990). All three found no difference in akinesia comparing the two groups.

These studies indicate that peribulbar and retrobulbar techniques appear to provide equivalent akinesia. However, the failure rates may be higher with one or the other approach depending on the exact injection technique employed.

Conclusion: There is no difference between peribulbar and retrobulbar anesthesia in achieving akinesia. [Evidence Grade: A]

#### Evidence Table 5. Local Anesthesia: Is there a difference between retrobulbar and subconjunctival/sub-Tenon's anesthetic blocks in achieving akinesia?

Two studies directly addressed this question. One large study (Kapran, Uyar, Eltutar et al., 1996) (570 subjects, quality score 25) compared sub-Tenon's to retrobulbar block and found that a higher percentage of patients in the sub-Tenon's group had complete akinesia (69 percent versus 41 percent) and fewer had poor akinesia (1 percent versus 7 percent). The second study (Khoo, Lim, and Yong, 1996) (106 subjects, quality score 46) reported similar akinesia with sub-Tenon's and retrobulbar block. However, 2 of 55 subjects in the sub-Tenon's group had residual movement that affected surgery, while none in the retrobulbar group had this problem.

The results of the two studies are inconsistent. However, the approaches used were not identical because the anesthetic agents were different in the two studies.

Conclusion: There is insufficient evidence in favor of either retrobulbar or subconjunctival/sub-Tenon's block for inducing akinesia. [Evidence Grade: I]

#### Evidence Table 6. Local Anesthesia: Is there a difference between peribulbar and subconjunctival/sub-Tenon's anesthetic block in achieving akinesia?

Two studies directly addressed this question. One study (Khurana, Sachdeva, Gombar et al., 1994) (200 subjects, quality score 30) found that subconjunctival/sub-Tenon's anesthesia was less successful than peribulbar block at producing akinesia (52 percent complete akinesia versus 85 percent). In addition, 19 percent in the subconjunctival/sub-Tenon's group had poor akinesia versus 8 percent in the peribulbar arm.

The second study was nonrandomized (Kollarits, Jaweed, and Kollarits, 1998) (200 subjects, quality score, 18) and found similar rates of complete akinesia in the peribulbar and sub-Tenon's groups (82 percent and 80 percent, respectively). Akinesia was assessed at the end of the case, however.

The results of the two studies are inconsistent. However, the techniques used were not identical.

Conclusion: There is insufficient evidence in favor of either peribulbar or subconjunctival/sub-Tenon's block for inducing akinesia. [Evidence Grade: I]

#### Evidence Table 7. Local Anesthesia: Summary of the evidence regarding peribulbar injection and akinesia

[Note: Studies (groups) where the technique was a combination of peribulbar and retrobulbar blocks are listed twice, once under each block type.] A total of 32 studies reported specific data on akinesia using peribulbar anesthesia. Nineteen of these (with 48 separate study groups) gave the percentage of patients with complete akinesia. Complete akinesia rates ranged from 26 percent to 100 percent.

Twenty-six percent of the studies reported that complete akinesia was achieved in 25 percent to 50 percent of patients; 25 percent of studies reported complete akinesia in 51 percent to 75 percent of patients; and 49 percent of the studies reported complete akinesia rates in over 75 percent of patients. One study reported 100 percent akinesia in all four study arms (Wong and Merrick, 1996). In one study (House, Hollands, and Schulzer, 1991), 5 of 14 arms had complete akinesia rates between 26 and 50 percent. In summary, 74 percent of the groups had greater than 50 percent of individuals with complete akinesia using a peribulbar block, even though a wide variety of techniques and agents were used.

A total of 15 studies (with 39 separate study groups) reported the rates of poor akinesia with peribulbar anesthesia. Poor akinesia rates ranged from 0 to 72 percent. Five arms (13 percent of study groups) reported that poor akinesia was achieved in over 40 percent of subjects. Three of these came from one study that assessed bupivacaine and lidocaine for peribulbar anesthesia (Loots, Koorts, and Venter, 1993). In general, however, the studies reported relatively low rates of poor akinesia with peribulbar block. Forty-four percent of study arms reported 10 percent or fewer patients had poor akinesia, 21 percent of studies reported poor akinesia in 11 to 20 percent of subjects, 13 percent of studies reported poor akinesia in 21 to 30 percent of subjects, and 10 percent reported poor akinesia in 31 to 40 percent of subjects.

One very large study, including over 1,000 individuals in each of three peribulbar arms, had complete akinesia in over 80 percent of cases and poor akinesia in 5 percent or fewer individuals in each of the three arms (Hamilton, Gimbel, and Strunin, 1988).

In summary, poor akinesia rates varied tremendously when peribulbar techniques were used. Nearly half of the studies reported rates below 10 percent, but 36 percent of studies reported rates over 20 percent.

#### Evidence Table 8. Local Anesthesia: Summary of the evidence regarding retrobulbar anesthesia and akinesia

[Note: Studies (groups) where the technique was a combination of peribulbar and retrobulbar blocks are listed twice, once under each block type.] A total of 20 studies reported specific data on akinesia using retrobulbar anesthesia. Thirteen of these (with 36 separate study groups) gave the percentage of patients with complete akinesia. Complete akinesia rates ranged from 23 percent to 100 percent.

One study reported a 23-percent complete akinesia rate in one of three arms (Ellingsson and Aasved, 1979). The other two arms had much higher rates (93 percent and 67 percent). The arm with the low rate used etidocaine 1 percent with hyaluronidase without epinephrine.

Fourteen percent of the studies reported complete akinesia in 25 percent to 50 percent of patients, 28 percent of studies reported complete akinesia in 51 percent to 75 percent of patients, and 58 percent of the studies reported complete akinesia rates above 75 percent. One study, which examined the effectiveness of sedation during cataract surgery, reported 100 percent akinesia in all six study arms (Boezaart, Berry, Laubscher et al., 1998).

In summary, 86 percent of the groups reported greater than 50 percent of patients with complete akinesia when using a retrobulbar block, even though a wide variety of techniques and agents was used.

A total of nine studies (with 22 separate study groups) reported the rates of poor akinesia with retrobulbar anesthesia. Wide variation was seen, as poor akinesia rates ranged from 0 to 63 percent. Two arms (9 percent of study groups) reported poor akinesia in over 40 percent of subjects. Thirty-six percent of studies reported 10 percent or fewer patients had poor akinesia, 27 percent of studies reported poor akinesia in 11 to 20 percent of subjects, 18 percent of studies reported poor akinesia in 21 to 30 percent of subjects, and 9 percent reported poor akinesia in 31 to 40 percent of subjects. In a report on seven groups in two studies (Sarvela, Nikki, and Paloheimo, 1993), five groups had poor akinesia in 20 percent of patients or more.

In summary, poor akinesia rates varied tremendously when using retrobulbar techniques. Thirty-six percent of the studies reported rates below 10 percent, while 36 percent of studies reported rates over 20 percent.

#### Evidence Table 9. Local Anesthesia: Is there evidence of the effectiveness of a subconjunctival/sub-Tenon's block in producing akinesia?

No study reported the percentage with complete akinesia. The percentage of subjects with poor akinesia was reported as 6 percent and 7 percent (Davis and O'Connor, 1989).

#### Evidence Table 10. Local Anesthesia: Is there evidence that adding hyaluronidase to local blocks produces better akinesia than not adding hyaluronidase?

Nine studies provided abstractable data on this question. Four studies found a large improvement in the akinesia rate with the addition of hyaluronidase. One study (Abelson, Mandel, Paradis et al., 1989) (40 subjects, quality score 46) had complete akinesia in 70 percent of those in whom hyaluronidase was used versus 40 percent in those without it. No patients receiving hyaluronidase had poor akinesia, as opposed to 15 percent in the control arm. Another study supporting the efficacy of hyaluronidase (Bjornstrom, Hansen, Otland et al., 1994) (54 subjects, quality score 30) had 78 percent with complete akinesia when hyaluronidase was used versus 26 percent in the control group. Two other studies showed large improvements in akinesia rates with hyaluronidase in some arms of the study (House, Hollands, and Schulzer, 1991; Sarvela and Nikki, 1992a). House, Hollands, and Schulzer (1991) reported 96 percent complete akinesia when using hyaluronidase with bupivacaine and lidocaine versus 46 percent without adding hyaluronidase. The improvement was less when adding hyaluronidase to bupivacaine alone. Sarvela and Nikki (1992a) reported the lowest complete akinesia rate and the highest poor akinesia rate in the one arm not receiving hyaluronidase.

One additional study found a slightly higher rate of complete akinesia with hyaluronidase. In Prosser, Rodney, Mian et al. (1996) (50 subjects, quality score 56), 84 percent of patients had complete akinesia with hyaluronidase versus 68 percent without it.

The final four studies found similar rates in the two groups. Two of these studies detected greater akinesia among the control group. One of these studies (Mindel, 1978) (27 subjects, quality score 35) had a 75-percent complete akinesia rate in the control group versus a 60-percent rate in those receiving hyaluronidase. A larger study (Krohn, Seland, Hovding et al., 1993) reported 93 percent complete akinesia in the control group and 83 percent in the hyaluronidase group. Finally, two studies (Nathan, Benrhaiem, Lotfi et al., 1996 [139 subjects, quality score 28]; Johansen, Kjeldgard, and Corydon, 1993 [20 subjects, quality score 41]) reported identical rates in two groups.

Conclusion: There is evidence that adding hyaluronidase to local blocks produces better akinesia than not adding hyaluronidase. [Evidence Grade: C]

#### Evidence Table 11. Local Anesthesia: Is there evidence that certain anesthetic agents used in local blocks produce better akinesia?

Nine controlled clinical trials directly compared anesthetic agents. Four studies looked at combinations of bupivacaine and lidocaine. One study (Davis and O'Connor, 1989) (54 subjects, quality score 53) found no difference between lidocaine 2 percent alone or when bupivacaine 0.5 percent was added. One study (Sarvela, Paloheimo, and Nikki, 1994) (82 subjects, quality score 58) found much higher rates of complete akinesia (95 percent versus 64 percent) when lidocaine 2 percent was added to bupivacaine 0.75 percent. A third study (Vettese and Breslin, 1985) (45 subjects, quality score 31) obtained nearly identical results comparing bupivacaine 0.5 percent with and without lidocaine 2 percent, but had much better akinesia when epinephrine was added to a block using both drugs. Only three groups were studied, so it is not clear if epinephrine added to bupivacaine alone would have had the same effect. The final study assessing these two agents (Loots, Koorts, and Venter, 1993) (151 subjects, quality score 45) reported slightly better results with bupivacaine 0.75 percent than bupivacaine 0.5 percent and no difference when lidocaine was added.

One study (Dopfmer, Maloney, Gaynor et al., 1996) (90 subjects, quality score 43) compared lidocaine 2 percent and bupivacaine 0.75 percent to prilocaine 3 percent for peribulbar anesthesia and found that prilocaine produced greater akinesia (61 percent with complete akinesia versus 26 percent).

One study (Huha, Ala-Kokko, Salomaki et al., 1999) (100 subjects, quality score 73) compared ropivacaine 1 percent to bupivacaine 0.75 percent. Complete akinesia rates were higher with bupivacaine (52 percent versus 32 percent).

Three studies compared etidocaine to other agents. One study with three arms (Ellingsson and Aasved, 1979) (92 subjects, quality score 20) found that etidocaine 1 percent was inferior to lidocaine 2 percent plus epinephrine and to etidocaine 1 percent plus epinephrine (93 percent complete akinesia and 4 percent poor akinesia with lidocaine versus 67 percent complete akinesia and 21 percent poor akinesia in the two arms where epinephrine was used). One study (Sarvela, 1993) (160 subjects, quality score 60) found etidocaine 1 percent and etidocaine 1.5 percent equivalent to bupivacaine 0.75 percent. One study (Thorburn, Thorn-Alquist, and Edstrom, 1976) (45 subjects, quality score 31) found etidocaine 1 percent and etidocaine 0.5 percent equal to mepivicaine.

Conclusions: Bupivacaine alone is as effective as bupivacaine and lidocaine at producing akinesia. [Evidence Grade: C]

Prilocaine produces better akinesia than a combination of bupivacaine and lidocaine. [Evidence Grade: C]

Lidocaine produces better akinesia than etidocaine. [Evidence Grade: C]

Bupivacaine produces better akinesia than ropivacaine. [Evidence Grade: C]

Etidocaine and bupivacaine produce similar akinesia. [Evidence Grade: C]

Etidocaine and mepivicaine produce similar akinesia. [Evidence Grade: C]

#### Evidence Table 12. Local Anesthesia: Is there evidence that the volume of anesthetic used and speed of injection affect akinesia or pain during the block or surgery?

Only one study (Gillart, Bazin, Montetagaud et al., 1998) (140 surgeries, quality score 50) addressed the question of the effect of volume on pain during the block or surgery, but the findings are difficult to interpret because of the study design. Two low volume (9 ml) and two higher volume (13.5 ml) groups were assigned to rapid and slow injection speeds. The study found no large differences in the percentages with no pain and with severe pain in any of the groups. However, a larger volume of injection (13.5 ml) yielded a higher range of akinesia for both slow and fast injections than did the smaller volume (9 ml) -- 54 percent versus 40 percent and 83 percent versus 60 percent, respectively.

The same study (Gillart, Bazin, Montetagaud et al., 1998) (140 surgeries, quality score 50) directly addressed the effect of injection speed and found that when agents were injected more rapidly, the percentage with complete akinesia was higher. Volume and speed of injection had no significant effect on pain during surgery.

Ortiz, Blanco, Serra et al. (1995) addressed the question of the effect of volume on akinesia. When hyaluronidase was added to the injection, a larger volume injected did not result in increased akinesia. However, when hyaluronidase was not used, increasing the volume of anesthesia injected resulted in improved akinesia.

Conclusions: Increasing the volume of anesthetic agent from 9 ml to 13.5 ml confers a greater likelihood of akinesia. [Evidence Grade: C]

There are insufficient data to determine if alterations in speed of injection or volume improve pain control during the block or surgery. [Evidence Grade: I]

#### Evidence Table 13. Local Anesthesia: Is there evidence that the retrobulbar block technique is more or less painful than peribulbar block during administration of the block?

Four studies directly addressed this question. Three articles reported only the mean pain score on a scale from 0 to 10. The first article (Saunders, Sturgess, Pemberton et al., 1993) (85 surgeries, quality score 36) reported a mean pain score of 3.8 with retrobulbar versus 3.3 with peribulbar block. The second study (Murdoch, 1990) (100 subjects, quality score 44) also reported slightly higher mean pain scores for retrobulbar than peribulbar block (5.8 versus 4.8). The third study (Weiss and Deichman, 1989) (79 subjects, quality score 56) also reported slightly higher scores with retrobulbar than peribulbar block (2.2 versus 1.8).

Only one study (Wong, Koehrer, Sutton et al., 1993) (150 subjects, quality score 65) reported on the distribution of scores, with 42 percent and 60 percent feeling no pain in the two retrobulbar groups, while 32 percent in the peribulbar group fell into this category. No subject in any of the groups experienced severe pain during administration of the block.

Conclusion: The evidence indicates that peribulbar injection is slightly less painful than retrobulbar injection. [Evidence Grade: C]

#### Evidence Table 14. Local Anesthesia: Is there evidence that retrobulbar block techniques are more painful for the patient while being administered than subconjunctival/sub-Tenon's block techniques?

All three studies directly addressing this question found less pain when administering subconjunctival/sub-Tenon's block than retrobulbar block. One study (Kapran, Uyar, Eltutar et al., 1996) (570 subjects, quality score 25) reported mild to moderate pain for all subjects using both methods, but mean pain scores were higher for the retrobulbar group (2.3 versus 1.8). The second article (Khoo, Lim, and Yong, 1996) (106 subjects, quality score 46) reported that patients had much less pain during the administration of the sub-Tenon's block than a retrobulbar block. Sixty-two percent reported no pain and no subjects reported severe pain with sub-Tenon's versus 2 percent with no pain and 16 percent with severe pain with a retrobulbar block.

The third study (Nielsen and Allerod, 1998) (130 subjects, quality score 59) compared retrobulbar, sub-Tenon's block, and topical anesthesia in subjects undergoing bilateral, simultaneous cataract extraction. The mean pain score (on a scale from 0 to 10) during administration of the block was low for both groups, but favored sub-Tenon's slightly (0.15 with sub-Tenon's block versus 0.87 with retrobulbar block).

Conclusion: The evidence indicates that pain during the administration of a subconjunctival/sub-Tenon's block is less than during retrobulbar block. [Evidence Grade: B]

#### Evidence Table 15. Local Anesthesia: Is there evidence that peribulbar techniques are more painful for the patient while being administered than subconjunctival/sub-Tenon's block techniques?

Two studies directly compared the pain during administration of sub-Tenon's anesthesia with peribulbar block. One study (Briggs, Beck, and Esakowitz, 1997) (131 surgeries, quality score 26) found that far more individuals in the sub-Tenon's arm than in the peribulbar arm had no pain during the block (55 percent versus 22 percent). In addition, only 4 percent experienced severe pain with sub-Tenon's versus 11 percent with peribulbar block. The second study (Kollarits, Jaweed, and Kollarits, 1998) (200 surgeries, quality score 18) documented very low rates of any pain with both techniques. Although sub-Tenon's block had more patients with no pain (99 percent versus 91 percent), these extremely high rates are difficult to reconcile with the rest of the literature regarding the pain of injection anesthetics.

Conclusion: There is insufficient evidence to determine whether a peribulbar versus subconjunctival/sub-Tenon's approach is less painful while the anesthetic is being administered. [Evidence Grade: I]

#### Evidence Table 16. Local Anesthesia: Summary of evidence on pain during administration of peribulbar block

[Note: Studies (groups) where the technique was a combination of peribulbar and retrobulbar blocks are listed twice, once under each block type]. A total of 13 studies addressed this question. Five studies with 12 arms reported the percentage with no pain during peribulbar injection, with a range of 0 to 85 percent. Four arms (33 percent) reported no pain in over 50 percent of subjects. One study (Bjornstrom, Hansen, Otland et al., 1994) (54 subjects, quality score 30) found that 85 percent of individuals given peribulbar injections with epinephrine and hyaluronidase had no pain versus 26 percent of those given the injection without these agents. Two of these 13 studies had 10 percent or fewer individuals report no pain with injection. The remaining six studies reported rates of 11 percent to 50 percent.

Eight arms of three studies reported the percentage of patients with severe pain during the injection. These percentages ranged from 0 to 50 percent, with 75 percent of studies reporting severe pain in 6 percent or fewer subjects. The one study with a 50-percent rate of severe pain (Bell and Butt, 1995) (60 surgeries, quality score 36) used a single peribulbar injection with lidocaine and hyaluronidase.

Seven of the studies reported mean pain scores. These give a sense of the amount of pain experienced by individuals but do not allow one to interpret whether or not the data are skewed, with many patients having no pain and some having a great deal of pain. Placing all reported scores on a scale from 0 to 10, the lowest mean score was 0.9 and the highest was 5.5. Seven (47 percent) of the arms had a mean score of 2.5 or less. Three arms (20 percent) had mean pain scores over 5 (Bell and Butt, 1995; Ursell and Spalton, 1996; Virkkila, Ali-Melkkila, and Kanto, 1992).

The amount of pain associated with peribulbar injections varied tremendously across the studies. This can be explained by the substantial variation in study design, including different approaches to measuring pain, different injection techniques, and different agents.

#### Evidence Table 17. Local Anesthesia: Summary of evidence regarding pain during administration of retrobulbar block

[Note: Studies (groups) where the technique was a combination of peribulbar and retrobulbar blocks are listed twice, once under each block type]. A total of eight studies addressed this question. Three studies with six arms reported the percentage with no pain during retrobulbar injection, with a range of 6 to 41 percent.

Eight arms of four studies reported the percentage of patients with severe pain during the injection. These percentages ranged from 9 to 33 percent.

Six of the studies reported mean pain scores. These give a sense of the amount of pain experienced by individuals but do not allow one to interpret whether or not the data are skewed, with many patients having no pain and some having a great deal of pain. Placing all reported scores on a scale from 0 to 10, the lowest mean score was 2.0 and the highest was 8.2. Five (33 percent) of the arms had a mean score of 2.5 or less.

The amount of pain associated with retrobulbar injections varied tremendously across the studies, but none of the studies used intravenous sedation prior to the retrobulbar block.

#### Evidence Table 18. Local Anesthesia: Summary of evidence regarding pain during administration of subconjunctival/sub-Tenon's block

Only one study (Guise, 1996) directly addressed pain during administration of a subconjunctival/sub-Tenon's block. In this study, 68 percent of patients reported no pain, 31 percent reported the pain to be mild or moderate, and 1 percent reported the pain to be severe. Of note, no systemic sedation was used.

#### Evidence Table 19. Local Anesthesia: Is there evidence that retrobulbar block is more or less painful for the patient during administration than topical block?

The only two studies to directly assess this question -- Patel, Clinch, Burns et al. (1998) (90 subjects, quality score 49) and Patel, Burns, Crandall et al. (1996) (128 subjects, quality score 52) -- found less pain on administration of retrobulbar than topical block. However, sedation was given "until unconsciousness" prior to administration of retrobulbar anesthesia.

Conclusion: There is insufficient evidence to compare pain during administration for topical versus retrobulbar block. [Evidence Grade: I]

#### Evidence Table 20. Local Anesthesia: Is there evidence that peribulbar block is more or less painful for the patient during administration than topical block?

Three of the four studies directly addressing this question found that peribulbar block resulted in more pain during administration than topical anesthesia. One study (Johnston, Whitefield, Giralt et al.,1998) (82 subjects, quality score 26) reported that the mean pain score was 2.5 out of 10 with peribulbar block versus 1.0 with topical anesthesia. Two articles reported on the distribution of pain scores during anesthetic administration, and both found significantly fewer subjects reporting no pain with peribulbar block than with topical anesthesia. One article (Roman, Auclin, and Ullern, 1996) (90 subjects, quality score 36) reported that no individuals reported pain with topical administration versus 22 percent of patients with mild to moderate pain with peribulbar block. The second article (Virtanen and Huha, 1998) (100 subjects, quality score 45) found that 92 percent had no pain with topical anesthesia, while only 4 percent of patients had no pain with peribulbar block.

One article (Uusitalo, Maunuksela, Paloheimo et al., 1999) (299 subjects, quality score 58) found similar amounts of pain with the administration of peribulbar and topical anesthesia (mean pain scores of 0.7 and 0.9, respectively), but intravenous sedation/anesthesia was routinely administered.

Conclusion: Topical anesthesia results in less pain during administration than a peribulbar block. [Evidence Grade: A]

#### Evidence Table 21. Local Anesthesia: Is there evidence that subconjunctival/sub-Tenon's block is more or less painful for the patient during administration than topical block?

The one study (Fukasaku and Marron, 1994) (348 subjects, quality score 11) that directly addressed this question compared two different subconjunctival/sub-Tenon's blocks to two topical groups. No patient in the two topical groups experienced pain during administration of anesthesia, while pain was variable in the subconjunctival/sub-Tenon's group, depending on technique.

Conclusion: There is evidence that topical anesthesia is less painful during administration than subconjunctival/sub-Tenon's block. [Evidence Grade: C]

#### Evidence Table 22. Local Anesthesia: Is there evidence that retrobulbar block results in more or less pain than peribulbar block during cataract surgery?

Four studies directly addressed this question. Two found virtually identical results using the two techniques. The first article (Sanders, Ahmed, Craig et al., 1997) (100 surgeries, quality score 19) reported the mean pain score from 0 to 10 as 0.2 for peribulbar block and 0.1 for retrobulbar block. Both groups had 90 percent with no pain and 0 percent with severe pain. The second study (Saunders, Sturgess, Pemberton et al., 1993) (85 surgeries, quality score 36) only reported mean pain scores, with peribulbar block averaging 0 and retrobulbar block averaging 0.1. The authors concluded that the two approaches yielded equivalent pain control during surgery.

One study (Murdoch, 1990) (100 subjects, quality score 44) reported slightly higher mean pain scores for retrobulbar than peribulbar block (2.6 versus 1.9), but did not report on the distribution of those scores. The last study (Wong, Koehrer, Sutton et al., 1993) (150 subjects, quality score 65) compared two retrobulbar techniques to a peribulbar technique. The result of the inferotemporal retrobulbar injection was similar to that of the peribulbar injection (90 percent no pain, 0 percent severe pain with retrobulbar versus 92 percent no pain and 0 percent severe pain with peribulbar). The superomedial retrobulbar injection performed slightly better, with all 50 subjects reporting no pain.

Conclusion: The evidence indicates that retrobulbar and peribulbar techniques produce equivalent pain control during cataract surgery. [Evidence Grade: A]

#### Evidence Table 23. Local Anesthesia: Is there evidence that retrobulbar block results in more or less pain than subconjunctival/sub-Tenon's block during cataract surgery?

Two of the three studies directly addressing this question found slightly better results with subconjunctival/sub-Tenon's block than with retrobulbar block. One study (Kapran, Uyar, Eltutar et al., 1996) (570 subjects, quality score 25) had no subjects without pain during surgery in either group. Six percent of subjects receiving retrobulbar blocks reported severe pain versus none in the subconjunctival/sub-Tenon's group. Mean pain scores on a 0 to 10 scale were higher for the retrobulbar group (2.7 versus 1.6). The second article (Khoo, Lim, and Yong, 1996) (106 subjects, quality score 46) reported much better pain control with subconjunctival/sub-Tenon's block than with retrobulbar block; 67 percent reported no pain and no subjects reported severe pain with subconjunctival/sub-Tenon's block versus 16 percent with no pain and 24 percent with severe pain with retrobulbar block.

The third study (Nielsen and Allerod, 1998) (130 subjects, quality score 59) compared retrobulbar, subconjunctival/sub-Tenon's, and topical anesthesia in subjects undergoing bilateral simultaneous cataract extraction. While the percentage with no pain was higher in the retrobulbar group (79 percent versus 64 percent), a larger number of subjects would not have retrobulbar anesthesia again (40 percent) than would not have subconjunctival/sub-Tenon's anesthesia again (16 percent).

Conclusion: The evidence indicates superior intraoperative pain control using subconjunctival/sub-Tenon's approaches compared with retrobulbar block. [Evidence Grade: B]

#### Evidence Table 24. Local Anesthesia: Is there evidence that peribulbar block results in more or less pain than subconjunctival/sub-Tenon's block during cataract surgery?

Only one controlled but nonrandomized trial directly addressed this question (Kollarits, Jaweed, and Kollarits, 1998) (100 subjects, quality score 18). The percentage of individuals with no pain during surgery was 76 percent in the peribulbar group and 79 percent in the subconjunctival/sub-Tenon's group. A second study also found similar results in the two groups (Briggs, Beck, and Esakowitz, 1997) (131 subjects, quality score 26), but did not present the data in a form that allowed one to determine the distribution or average of the pain scores.

Conclusion: There is insufficient evidence in the literature to determine if peribulbar or subconjunctival/sub-Tenon's block results in better pain control during cataract surgery. [Evidence Grade: I]

#### Evidence Table 25. Local Anesthesia: Summary of the evidence regarding pain during cataract surgery after peribulbar block

[Note: Studies (groups) where the technique was a combination of peribulbar and retrobulbar blocks are listed twice, once under each block type]. Twenty articles presented data on the effectiveness of peribulbar block at producing pain control. Nine articles with 16 arms presented mean scores for pain during surgery. Scores ranged from 0.1 (out of 10) to 1.9. Only three of the arms had scores over 1.0.

Thirteen studies reported the percentage with complete pain control during cataract surgery with peribulbar block. The percentage was 90 percent or greater in 16 (64 percent) of the 25 arms studied. The lowest reported rate of complete pain control was 74 percent.

#### Evidence Table 26. Local Anesthesia: Summary of the evidence regarding pain control during cataract surgery after retrobulbar block

[Note: Studies (groups) where the technique was a combination of peribulbar and retrobulbar blocks are listed twice, once under each block type]. Five articles presented data on the effectiveness of retrobulbar block at producing pain control. Two articles with eight arms presented mean scores for pain during surgery. The first study (Boezaart, Berry, Laubscher et al., 1998) (240 subjects, quality score 71) had six arms with mean pain scores all less than 0.7 (0-10 scale). The second article (Krause, Weindler, and Ruprecht, 1997) (70 subjects, quality score 42) investigated the effect of warming on retrobulbar blocks and found a mean pain score of 4.5 and 5.3 in the two groups. These are particularly high scores for pain during cataract surgery. That same study reported that no subjects had complete pain control and 26 percent and 31 percent had severe pain in the two retrobulbar groups. No other study in this review reported such poor results with retrobulbar anesthesia.

The remaining three studies that reported the percentage with no pain during cataract surgery had five arms. Two arms of one study reported 63 percent of patients with complete pain control. Two arms of another study reported 83 percent and 93 percent of patients had complete pain control, and the final study reported 100 percent of patients had complete pain control.

#### Evidence Table 27. Local Anesthesia: Summary of the evidence regarding pain during cataract surgery after subconjunctival/sub-Tenon's injection

Five arms of four studies assessed pain during the surgery following administration of subconjunctival/sub-Tenon's block. Three studies reported the percentage of patients with no pain when a sub-Tenon's approach was used. One study (Fukasaku and Marron, 1994) reported that in one arm 85 percent of patients had no pain and 1.5 percent had severe pain, and in another arm 99 percent of patients had no pain. The approach used in the latter, less painful sub-Tenon's technique involved incising the conjunctiva 8 to 12 mm posterior to the superior limbus and using a blunt, curved cannula to inject 1 cc of lidocaine in the sub-Tenon's space. The second study reported 64 percent of patients had no pain and 0 percent had severe pain with sub-Tenon's block. The third study reported 90 percent of patients had no pain during surgery after a sub-Tenon's block.

One study reported the mean pain score during surgery. Using a sub-Tenon's approach, Manners and Burton (1996) reported a mean pain score of 0 (scale 0 to 10) in 25 subjects. Patients were asked after the surgery was completed to recall the pain felt during the procedure.

#### Evidence Table 28. Local Anesthesia: Is there evidence that retrobulbar block results in more or less pain during cataract surgery than topical block?

All four studies that directly addressed this question reported a higher percentage of subjects receiving retrobulbar blocks had complete pain control during surgery than did subjects receiving topical anesthesia. One study (Jolliffe, Abdel-Khalek, and Norton, 1997) (40 subjects, quality score 50) reported 32 percent of patients had no pain in the topical group versus 48 percent of patients in the retrobulbar group. Additionally, this study reported 21 percent of patients in the topical group had severe pain versus 5 percent of patients in the retrobulbar group. The second article (Nielsen and Allerod, 1998) (130 subjects, quality score 59) compared retrobulbar, subconjunctival/sub-Tenon's, and topical anesthesia in subjects undergoing bilateral simultaneous cataract extraction: 79 percent receiving retrobulbar block reported no pain, while only 44 percent receiving topical anesthesia did so.

The last two studies reported 91 percent of patients had no pain during surgery after retrobulbar block compared to 83 percent with topical anesthesia (Patel, Burns, Crandall et al., 1996) (138 subjects, quality score 52) and 89 percent of patients had no pain during surgery after retrobulbar block versus 69 percent with topical anesthesia (Patel, Clinch, Burns et al., 1998) (90 subjects, quality score 49).

Conclusion: Retrobulbar block results in less pain during cataract surgery than topical anesthesia. [Evidence Grade: A]

#### Evidence Table 29. Local Anesthesia: Is there evidence that peribulbar block results in more or less pain than topical block during cataract surgery?

Three of the five studies directly addressing this question found that peribulbar block resulted in less pain during surgery than topical anesthesia. One study (Johnston, Whitefield, Giralt et al., 1998) (82 subjects, quality score 26) reported that the median pain score was 2 out of 10 with topical anesthesia versus 0 with peribulbar block. The second article (Uusitalo, Maunuksela, Paloheimo et al., 1999) (299 subjects, quality score 58) reported that 93 percent of patients had no pain and none had severe pain in the peribulbar group, as opposed to 70 percent of patients with no pain and 4 percent with severe pain in the topical group. The third study (Virtanen and Huha, 1998) (100 subjects, quality score 45) used a scleral tunnel technique and found that 76 percent of patients had no pain and none had severe pain in the peribulbar group, while only 12 percent of patients had no pain and 2 percent had severe pain in the topical group.

The two articles that reported similar results in the two groups assigned individuals to receive topical anesthesia in one eye and peribulbar block in the other eye. One article (Roman, Auclin, and Ullern, 1996) (90 subjects, quality score 36) reported similarly high percentages with no pain (96 percent in the peribulbar group versus 93 percent in the topical group), but patients all received intravenous sedation/anesthesia. The second study (Zehetmayer, Radax, Skorpik et al., 1996) (72 subjects, quality score 54) reported identical mean scores with both approaches.

Conclusion: Peribulbar block results in less pain during cataract surgery than topical anesthesia. [Evidence Grade: B]

#### Evidence Table 30. Local Anesthesia: Is there evidence that subconjunctival/sub-Tenon's block results in more or less pain during cataract surgery than topical anesthesia?

Three studies addressed this question directly. The first study that directly addressed this question (Fukasaku and Marron, 1994) (348 subjects, quality score 11) compared two different subconjunctival/sub-Tenon's blocks to two different approaches to topical anesthesia. In one arm, more pain during surgery was reported by patients receiving subconjunctival/sub-Tenon's anesthesia (85 percent with no pain and 2 percent with severe pain). In the two topical arms, 78 percent of patients (using a soaked pledget) and 69 percent (using drops alone) had complete absence of pain during cataract surgery, and none had severe pain. The second article (Nielsen and Allerod, 1998) (130 subjects, quality score 59) compared retrobulbar, sub-Tenon's, and topical anesthesia in subjects undergoing bilateral, simultaneous cataract extraction. Sixty-four percent receiving subconjunctival/sub-Tenon's block reported no pain, while only 44 percent receiving topical anesthesia did so. The final study reported a mean pain score of 0.4 using topical versus 0.02 with subconjunctival/sub-Tenon's (Manners and Burton, 1996).

Conclusion: The data indicate that subconjunctival/sub-Tenon's block results in less pain during cataract surgery than topical anesthesia. [Evidence Grade: C]

#### Evidence Table 31. Local Anesthesia: Is pain control improved by adding intracameral lidocaine to topical anesthesia?

All four randomized clinical trials evaluating the effectiveness of adding intracameral lidocaine to topical anesthesia found that intracameral lidocaine improves pain control during cataract surgery (Carino, Slomovic, Chung et al., 1998; Crandall, Zabriskie, Patel et al., 1999; Gills, Cherchio, and Raanan, 1997; Tseng and Chen, 1998). One of these (using no routine sedation) found only slight overall improvement in pain control but reported that patients complained less of tissue manipulation with the use of intracameral lidocaine (Crandall, Zabriskie, Patel et al., 1999). Two of the remaining three articles used no sedation and found intracameral lidocaine decreased patient-reported pain. No pain was experienced by 77 percent in the intracameral group versus 47 percent in the control in one study (Carino, Slomovic, Chung et al., 1998), and 90 percent versus 74 percent in the other (Gills, Cherchio, and Raanan, 1997). The final article reported on patients receiving oral sedation prior to surgery. Patients reported no pain in 67 percent of the intracameral group versus 49 percent of the controls (Tseng and Chen, 1998). This study also reported that tissue manipulation (particularly touching the iris) was more uncomfortable without intracameral lidocaine.

Conclusion: Studies consistently demonstrated better pain control during surgery using intracameral lidocaine. [Evidence Grade: B]

#### Evidence Table 32. Local Anesthesia: Is there evidence that hyaluronidase added to the block decreases the pain experienced during the block?

One article (House, Hollands, and Schulzer, 1991) reported that 100 percent of subjects experienced no pain during surgery in six of seven arms of a study looking at various combinations of anesthetic agents. Only one patient in the final arm (which was one of the two arms that did not use hyaluronidase) experienced any pain.

Conclusion: There is insufficient evidence in the literature to address this question. [Evidence Grade: I]

#### Evidence Table 33. Local Anesthesia: Is there evidence that certain anesthetic agents used in local blocks produce better control of pain during cataract surgery?

Six studies directly addressed this question and reported abstractable data. Four studies examined lidocaine and bupivacaine in at least one arm. One study (Dopfmer, Maloney, Gaynor et al., 1996) (90 subjects, quality score 43) compared lidocaine 2 percent and bupivacaine 0.75 percent to prilocaine 3 percent for peribulbar anesthesia and found a slightly higher rate of pain control with prilocaine (98 percent of patients with no pain) than with the combination of lidocaine and bupivacaine (93 percent of patients with no pain). Another study (Henderson and Franks, 1996) (75 subjects, quality score 37) only reported the mean pain score (0-10 scale) with prilocaine 2 percent versus bupivacaine and lidocaine and found very similar scores (1.2 and 0.9, respectively). One study (Loots, Koorts, and Venter, 1993) (151 subjects, quality score 45) compared bupivacaine to a combination with lidocaine and found 100 percent of patients had complete pain control in all groups. The third study (House, Hollands, and Schulzer, 1991) (117 subjects, quality score 51) compared various combinations of bupivacaine, lidocaine, hyaluronidase, and epinephrine and found that eight of nine groups had complete pain control in all patients, with the final group having only one individual with less than perfect pain control during surgery.

One study (Huha, Ala-Kokko, Salomaki et al., 1999) (100 subjects, quality score 60) compared ropivacaine 1 percent to bupivacaine 0.75 percent. Eighty-eight percent of patients in both groups experienced no pain during the surgery.

The final study (Gutman, Sinskey, and Cain, 1979) (52 subjects, quality score 34) reported 93 percent of patients had no pain during surgery and none had severe pain with lidocaine, as opposed to 100 percent of patients having no pain during surgery with etidocaine.

Conclusion: All agents reported had high rates of excellent pain control during surgery. There are insufficient data in the literature to determine if these agents are truly equivalent in controlling pain during surgery. [Evidence Grade: I]

#### Evidence Table 34. Local Anesthesia: Is there evidence that warming the anesthetic results in better akinesia, less pain during the block, or less pain during the operation than not warming the agents?

Three studies directly addressed this question. One study (Bell and Butt, 1995) (60 surgeries, quality score 36) reported only on the percentage experiencing no pain during the block. Three percent of patients receiving warmed anesthetic, as opposed to no patients with room-temperature anesthetic, reported no pain during the block. The second study (Ursell and Spalton, 1996) (40 subjects, quality score 49) reported lower mean pain scores (0-10 scale) during the injection with warming of the anesthetic than without warming (3.6 versus 5.3).

The final study (Krause, Weindler, and Ruprecht, 1997) (70 subjects, quality score 42) reported higher rates of complete akinesia with than without warming of lidocaine (77 percent versus 60 percent).

Conclusion: There is insufficient and inconclusive data to determine if warming of anesthetic agents improves their performance during cataract surgery. [Evidence Grade: I]

#### Evidence Table 35. Local Anesthesia: Is there evidence that raising the pH of the local anesthetic yields more effective or more comfortable local blocks?

Three studies assessed directly the effects of pH adjustment on block effectiveness. One study (Lewis, Hamilton, Brant et al., 1992) reported only the percentage of patients with poor akinesia: 35 percent in the pH 5.4 group and 25 percent in the pH 6.8 group. Another study (Zehetmayer, Rainer, Turnheim et al., 1997) reported only the mean pain score (0-10 scale) during surgery, which was 0.98 in the pH 7.2 group and 1.0 in the pH 5.2 group. A third study (Hinshaw, Fiscella, and Sugar, 1995) reported only the mean pain of the block administration itself, 6.0 for the pH 6.7 group and 8.2 for the pH 6.04 group (0-10 scale).

Conclusion: pH adjustment of the anesthesia agent used in a local block has no effect on the block's effectiveness. [Evidence Grade: C]

#### Evidence Tables 36, 37, 38, and 39. Local Anesthesia: These tables summarize the data on ocular and systemic complications reported with retrobulbar, peribulbar, subconjunctival/sub-Tenon's, and topical anesthesia

[Note: Studies (groups) where the technique was a combination of peribulbar and retrobulbar blocks are listed twice, once under each block type]. The range of values for the frequency of the major ocular and systemic complications is presented in these tables. However, complications were rarely and not systematically presented in the literature. The most important ocular complications (e.g., globe perforation) are sufficiently rare in incidence that the reported frequency in a given study is almost invariably zero. The situation is analogous for significant medical complications (e.g., stroke). Furthermore, the definitions used for many of the complications reported (e.g., ptosis) are so variable that it is difficult to compare rates of complications across studies.

In order to assess the complications associated with different approaches to local anesthesia, we reviewed all case series with 1,000 or more cases. By far the largest series presented consisted of 12,000 cases (Hamilton, Gimbel, and Strunin, 1988), about half of whom received retrobulbar blocks and half of whom received peribulbar blocks. There were 8 cases of brainstem anesthesia with respiratory arrest in 5,235 retrobulbar block cases (0.15 percent). An additional five patients had central nervous system (CNS) abnormalities without respiratory arrest. No cases of CNS block were reported in 5,704 peribulbar injections. Data on retrobulbar hemorrhage were reported only for one of the two retrobulbar block groups, with 5 cases of "moderate" hemorrhage out of 3,595 retrobulbar block cases (0.14 percent). Only one case of scleral perforation was reported in the 5,235 retrobulbar patients, and none occurred in the peribulbar groups.

Another study reported no cases of scleral perforation in over 4,000 operations using either retrobulbar or peribulbar techniques (Waller, Taboada, and O'Connor, 1993). One study of 1,600 cases of peribulbar injections reported no cases of scleral perforation, brainstem anesthesia, or retrobulbar hemorrhage (Davis and Mandel, 1986). Hendrick, Rosenberg, and Lebenbom-Mansour (1997) reported no cases of scleral perforation, brainstem anesthesia, or retrobulbar hemorrhage using peribulbar blocks in 1,074 cases.

In summary, large case series indicate that severe complications are rare with peribulbar and retrobulbar block. The major risk factor for scleral perforation is the axial length of the eye, longer eyes having greater risk.

One study reported on the complication rates when using topical anesthesia in combination with a lid block (Hodgkins, Teye-Botchway, Morrell et al., 1992). The authors reported one case of expulsive choroidal hemorrhage in 1,817 cases.

No severe complications were reported with subconjunctival/sub-Tenon's anesthesia, although conjunctival chemosis and subconjunctival hemorrhage are common.

### Evidence Regarding Sedation Strategies

The following section summarizes the evidence regarding sedation strategies, using the same reporting approach used for the section on local anesthesia. Synthesis of the evidence in this section was significantly limited by the heterogeneity in and lack of standardization of the outcomes reported.

#### Evidence Tables 40, 41, and 42. Sedation: Is intravenous or intramuscular sedation superior to local anesthesia alone for pain control, patient cooperation, anxiety control, and patient satisfaction?

Three studies directly addressed this question. Wong and Merrick (1996) (120 subjects, quality score 86) randomized cataract surgery patients to placebo, intravenous benzodiazepines, intravenous opiates, or a combination of benzodiazepines and opiates. Intravenous sedation/anesthesia was associated with a larger percentage of patients reporting excellent satisfaction (100 percent versus 93 percent) and a small reduction in recall of pain during the block (median pain scores 0.6, 0.9, and 1.2 in the groups receiving sedation and/or anesthesia versus 1.4, in the group receiving placebo, 0-10 scale), although the differences for both outcome measures were marginal. Pac-Soo, Deacock, Lockwood et al. (1996) performed a randomized clinical trial (49 subjects, overall quality score 77) and evaluated patient-controlled analgesia with midazolam or propofol versus no patient-controlled analgesia. Intravenous sedation/anesthesia was associated with reduced anxiety (0.5 versus 1.5, p < 0.05, 0-10 scale). There were no differences in blood pressure between the nonsedated and the sedated group. One study evaluated intramuscular analgesia compared to placebo (Virkkila, Ali-Melkkila, and Kanto, 1992) (90 subjects, overall quality score 76). Intramuscular opiates (mean score 3.5) were superior to intramuscular midazolam (mean score 4.5) and placebo (mean score 5.4) regarding reduction in pain during the block. Intramuscular analgesia or sedation was associated with increased bradycardia, and less intraoperative anxiety compared to no intramuscular agent.

Conclusion: Intravenous or intramuscular sedation/analgesia is associated with a modest improvement in anxiety, pain relief, and patient satisfaction. [Evidence Grade: C]

#### Evidence Tables 43, 44, and 45. Sedation: Summary of evidence on the effectiveness and safety of oral and intramuscular sedation

Other studies that provide some information about the effectiveness of oral or intramuscular sedation in cataract surgery are summarized in Evidence Tables 43, 44, and 45. Evidence Table 43 summarizes the data on patient cooperation and pain. Evidence Table 44 summarizes the data on patient anxiety and satisfaction, and Evidence Table 45 summarizes the data on medical outcomes and hemodynamics. The primary aim of these studies was not to compare different sedation strategies, but they provide data on patients who received only oral or intramuscular sedation. A total of 22 studies included only oral sedation. Several studies with oral sedation reported pain scores. Boezaart, Berry, Laubscher et al. (1998) used oral sedation and reported mean scores for pain during the block of 1.95 to 2.52 (on a 0 to 10 scale), depending on regional technique. Zehetmayer, Radax, Skorpik et al. (1996) and Zehetmayer, Rainer, Turnheim et al. (1997) reported mean pain scores from 0.1 to 1.1 (on a 0 to 10 scale) in two studies employing oral analgesia.

Only one study reported on patient anxiety. Oikkonen (1994) reported that 20 percent of patients reported no anxiety during the case with oral sedation alone. None of the studies reported on patient satisfaction. Ali-Melkkila, Virkkila, Leino et al. (1993) reported on the percent of patients who would desire the same management again; 99 percent of patients said they would choose oral sedation again. Jolliffe, Abdel-Khalek, and Norton (1997) reported that approximately 87 percent of patients desired the same oral sedation management strategy again. Only one study that employed oral sedation reported any medical complications. Saunders, Sturgess, Pemberton et al. (1993) reported that 2 percent of patients developed postoperative congestive heart failure. No study reported any hemodynamic complications. The need for supplemental intravenous analgesics was reported in several studies. Ali-Melkkila, Virkkila, Leino et al. (1993) reported that 3 percent of patients receiving oral sedation with lorazepam required supplemental fentanyl. Sarvela (1993) reported a 4-percent incidence of requiring supplemental fentanyl.

A total of six studies employed intramuscular sedation. Virkkila, Ali-Melkkila, and Kanto (1992) reported mean pain scores during the block of 3.5 to 5.4 on a 0 to 10 scale. No study using intramuscular sedation evaluated anxiety, patient satisfaction, or the percentage of patients desiring the same management strategy. No medical complications were evaluated in any study using intramuscular sedation. Hemodynamics were evaluated in the study by Virkkila, Ali-Melkkila, and Kanto (1992). Intramuscular analgesia was only associated with bradycardia and no other complications. Approximately 5 percent of patients required supplemental analgesia in two of the studies.

In summary, oral and intramuscular sedation are associated with moderate pain during the block, little pain during surgery, and a small requirement for supplemental intravenous sedation.

#### Evidence Tables 46, 47, and 48. Sedation: Summary of the evidence on the effectiveness of intravenous sedation regarding patient cooperation, pain, anxiety, satisfaction, and medical and hemodynamic complications

Evidence Table 46 summarizes data on patient cooperation and pain. Evidence Table 47 summarizes the data on patient anxiety, and Evidence Table 48 summarizes the data on medical outcomes and hemodynamics. Studies were separated according to class of agent.

Eight studies assessed benzodiazepines. Two of these studies assessed pain during surgery (Anderson, 1995; Anderson, Nath, and Anderson, 1999), reporting that 90 percent and 88 percent of patients had no pain during surgery. Only one study (Wong and Merrick, 1996) reported on patient satisfaction, and all patients were satisfied with the anesthesia management. No medical complications were reported in any of these studies, and the only hemodynamic complication was bradycardia (3 percent) (Virkkila, Ali-Melkkila, and Kanto, 1992). There was a rare need for supplemental oxygen in 1.7 percent of patients. In the study by Anderson (1995), 1 percent of patients required supplemental intravenous sedation.

In three studies, barbiturates were evaluated. In one study (Patel, Burns, Crandall et al., 1996), the percentage with no pain during the block was reported at 96 percent and no pain during surgery was reported in 9 percent of patients. Overall mean pain scores during the block were extremely low. Anxiety and patient satisfaction were not reported in these studies. No medical or hemodynamic complications were reported. Supplemental analgesics were required in 1 percent of patients in the study by Patel, Burns, Crandall et al. (1996).

Analgesics were used as the only class of sedative agent in at least one group in nine studies. Pappa, Pouliou, Nastou et al. (1995) reported that 50 percent of patients had severe pain using retrobulbar regional anesthesia alone without topical EMLA. The mean pain score (on a 0 to 10 scale) during the block was 3.0 in this group compared to 1.85 when EMLA was placed on the skin before the injection. No other study directly assessed pain. Uusitalo, Maunuksela, Paloheimo et al. (1999) reported on patient satisfaction, with 5 percent of patients receiving intravenous sedation/anesthesia having fair to poor satisfaction with the anesthesia received. No medical or hemodynamic complications were reported from any of these studies.

Three studies reported on the use of propofol alone. Only one study (Gillart, Bazin, Montetagaud et al., 1998) reported the percentage of patients who had no pain during the block, which was approximately 48 percent overall. There were no major medical complications, and supplemental oxygen was rarely needed.

Propofol was included as part of the sedation/anesthesia regimen in three studies. Kost and Emerson (1992) evaluated patient satisfaction with a combined analgesic/propofol regimen, with only 30 percent reporting very good to excellent satisfaction. The need for supplemental oxygen was the only medical or hemodynamic complication that was reported in any of these studies; it occurred in 4 percent to 40 percent of patients.

The combination of benzodiazepine and analgesic in the two studies by Patel, Burns, Crandall et al. (1996) and Patel, Clinch, Burns et al. (1998) (138 subjects, quality score 52; 90 subjects, quality score 49) demonstrated that only 60 percent to 70 percent of patients had no pain during the block and during surgery. Only 3 percent of patients receiving this combination reported excellent satisfaction in the study by Kost and Emerson (1992) (74 subjects, quality score 48).

In summary, no one class of agent or combination of agents appears superior to another for sedation.

#### Evidence Tables 49, 50, and 51. Sedation: Is one class of sedative associated with improved outcome compared to another class?

A total of 12 randomized clinical trials directly compared one class of intravenous sedative/anesthetic to another class or a combination of classes. Three studies directly addressed the comparison of benzodiazepines against another class of drug. Pac-Soo, Deacock, Lockwood et al. (1996) (49 subjects, quality score 63) compared benzodiazepines with propofol and found that surgeons reported greater patient cooperation and less need for supplemental oxygen in the propofol group. Virkkila, Ali-Melkkila, and Kanto (1992) (49 subjects, quality score 63) compared benzodiazepines to analgesics and reported lower pain scores during the block in the analgesic group (mean 3.5 versus 4.5, p < 0.001 on a scale from 0 to 10) without increased need for supplemental oxygen. Wong and Merrick (1996) (90 subjects, quality score 76) also compared benzodiazepines to analgesics and reported an increased need for supplemental oxygen in the analgesic group.

Two studies by Patel, Burns, Crandall et al. (1996) and Patel, Clinch, Burns et al. (1998) compared barbiturates to combinations of benzodiazepines and analgesics. Both studies demonstrated that a greater percentage of patients in the barbiturate group reported no pain during both the block and surgery.

A group containing propofol alone was included in three studies, with an additional three studies including a combined propofol/analgesic group. Kost and Emerson (1992) reported higher patient satisfaction in the propofol and analgesic group compared to the benzodiazepine and analgesic group. The study by Yee, Burns, Mann et al. (1996) (30 subjects, quality score 44) was the only study in which a higher incidence of need for supplemental oxygen was reported with propofol compared to propofol and analgesics.

The remaining studies compared combinations of sedative and analgesic medications in single or escalating dosages. Gilbert, Holt, Johnston et al. (1987) (55 subjects, quality score 67) reported greater patient satisfaction with a combination of barbiturate and analgesic compared to a combination of benzodiazepine and analgesic (74 percent versus 43 percent, p < 0.019).

Conclusion: There is insufficient evidence to suggest that one analgesic regimen is superior to another. [Evidence Grade: I]

#### Evidence Tables 52 and 53. Sedation: Is patient-controlled analgesia safe and effective?

Two studies directly assessed the value of intravenous patient-controlled analgesia and sedation. Herrick, Gelb, Nichols et al. (1996) (55 subjects, quality score 61) evaluated the effectiveness of intravenous patient-controlled propofol versus placebo. Patients demonstrated marginally improved satisfaction with patient-controlled propofol, with only a minor increase in the need for supplemental oxygen. Pac-Soo, Deacock, Lockwood et al. (1996) compared patient-controlled sedation with placebo, midazolam, and propofol (49 subjects, quality score 63). They demonstrated reduced anxiety, with only a mild increase in the need for supplemental oxygen in the groups receiving intravenous medications. Both of the studies employed small cohorts of patients. Patient-controlled sedation is not a common approach and may not be generalizable to other clinical scenarios.

Conclusions: There is evidence to suggest that patient-controlled analgesia is an effective method of supplying intravenous sedation, but there is also evidence suggesting an increased need for supplemental oxygen. [Evidence Grade: C]

There is insufficient evidence to assess patient-controlled analgesia in comparison to other common methods of delivering sedation. [Evidence Grade: I]