# Methodology

In October 1998, the U.S. Agency for Health Care Policy and Research, now renamed the Agency for Healthcare Research and Quality (AHRQ), awarded a contract to the Johns Hopkins University Evidence-based Practice Center (EPC) to prepare an evidence report on the management of local anesthesia and sedation during surgery for age-related cataract. The task was to formulate a report that incorporated the best available evidence on this topic. The project consisted of recruiting a group of experts, identifying a target patient population, identifying relevant questions, performing a comprehensive literature search, constructing evidence tables, performing a decision analysis, and submitting the report for extensive peer review.

## Recruitment of Experts

We identified a core group of five clinically oriented technical experts who provided key input to the project. This group included a representative of the principal partner, the American Academy of Ophthalmology. The core group of technical experts included:

- Jacqueline Harden, CRNA, a Certified Registered Nurse Anesthetist in private practice in Atlanta, Georgia.
- Marc A. Feldman, M.D., M.H.S., Director of Ophthalmic Anesthesia, Cleveland Clinic Foundation, an anesthesiologist with both methodological training and extensive clinical experience.
- Stephen A. Obstbaum, M.D., Clinical Professor of Ophthalmology at New York University and Chief of Ophthalmology at the Lenox Hill Hospital in New York City, an experienced cataract surgeon who has served as the president of both of the two leading professional organizations in ophthalmology (the American Academy of Ophthalmology and the American Society of Cataract and Refractive Surgery). Dr. Obstbaum represented the American Academy of Ophthalmology.
- Brent G. Petty, M.D., Associate Professor of Medicine at the Johns Hopkins University School of Medicine, an experienced clinician who directed the Medical Consultation Service for the Wilmer Eye Institute from 1979 to 1997. He also has extensive experience in evidence-based medicine.
- Harry C. Wong, M.D., Emeritus Professor of Anesthesiology at the University of Utah, an anesthesiologist who is internationally recognized as an expert in ambulatory anesthesia, particularly with respect to issues of safety and quality assurance.

Representatives were identified from a range of other stakeholder organizations, including the American Association of Family Physicians (AAFP), the American Association of Nurse Anesthetists (AANA), the American Society of Anesthesiologists (ASA), the American Society of Cataract and Refractive Surgery (ASCRS), Blue Cross/Blue Shield, the Society for Ambulatory Anesthesia (SAMBA), and the Health Care Financing Administration (HCFA). These individuals aided in the identification of the relevant questions and served as peer reviewers of the evidence report. These peer reviewer representatives included physicians, nurse anesthetists, and representatives of professional organizations, government agencies, health plans, and industry (Appendix A). We contacted a number of consumer (patient) organizations but were not able to recruit a representative. However, a representative from the Anesthesia Patient Safety Foundation was identified and participated as a peer reviewer.

## Patient Population

The target population addressed by this evidence report is adult patients undergoing surgery for age-related cataract under local anesthesia with or without systemic sedation in ambulatory surgery centers and hospital settings. The target audience is health care professionals involved in the care of adult patients undergoing surgery for cataract.

## Identifying the Specific Questions

The study team devised an initial list of potential questions. The preliminary list of questions was discussed with ophthalmologists and anesthesiologists external to the study team to add other relevant questions. Following these discussions, the study investigators prepared a letter that included a list of the potential questions regarding the management of anesthesia for cataract surgery (Appendix B). Through the use of this letter, each technical expert and peer reviewer was asked to rate independently the importance of each proposed question from the perspective of his/her own profession or organization. Based on the responses to the letter and a conference call with the technical experts, we concluded that the literature review would focus on the key areas of regional anesthesia, sedation, and patient characteristics. The following questions were identified to be addressed in the evidence report:

1. What are the risks and benefits associated with use of one form of regional anesthesia over another? This question includes issues relating to patient characteristics, complications, choice of agents, training, and use of supplemental measures to enhance local anesthesia performance (e.g., heat and pH adjustment).
2. What are the risks and benefits associated with different approaches to sedating the patient for cataract surgery? This question also includes issues related to patient characteristics, complication rates, specific sedative strategies, level and intensity of monitoring, and the presence of evidence supporting the use of sedation.

## Casual Pathway

Having defined the questions to be addressed in the evidence report, we constructed a model of the causal pathway of anesthesia management for cataract surgery (Appendix C). Patient outcomes are influenced by all the factors shown. The provider factors are specialty, geographic location, and personnel.

Patient factors such as age and medical and ocular comorbidities are certain to influence outcomes such as recovery time and patient satisfaction. Health system factors, including where the procedure is performed, might also impact the results. One might postulate that medically complicated patients who undergo surgery in ambulatory settings might be at greater risk of having a poor outcome if a rare adverse medical event (e.g., acute myocardial infarction) occurs.

During surgery there is a complex interaction between the anesthesia management strategy, surgical technique, and patient factors that may influence outcomes. Ophthalmic anesthesia involves the use of injection techniques or eye drops to control local pain in the eye. Choice of ophthalmic anesthesia technique may influence the concentration and choice of preoperative or intraoperative sedation agents, which in turn affect the level of monitoring. For example, deep sedation is often used just prior to administering a retrobulbar block. This may increase the need for medical interventions during surgery, especially if the patient is frail. This in turn may increase the intensity of monitoring that is required to complete the surgery safely. Initial deep sedation may not be needed with topical anesthesia, but ongoing intraoperative sedation might be required throughout the duration of the surgery using this approach. Patient satisfaction and his/her assessment of pain control may also depend on the type of sedatives used as well as the level of sedation. Amnestic agents may cause the patient to forget the pain that was felt during an operation. Deep sedation may increase patient satisfaction if the patient prefers to sleep through the operation.

Finally, surgeon factors such as operating speed may greatly influence the anesthesia needs and patient outcomes. A 10-minute procedure is less likely to result in adverse anesthesia-related events than one that takes over an hour. If pain is felt, its impact is brief when the surgery is performed rapidly.

## Literature Search Methods

### Sources

Several literature sources were used in order to identify all studies that were potentially relevant to the study questions examined in this evidence report. Preliminary searches were completed on PubMed, the online free access to MEDLINE provided by the National Library of Medicine. The results of these searches were used in the refinement of the questions and formed the basis for the database of citations used for this evidence report.

The electronic searches were conducted in PubMed and CENTRAL, the Cochrane Collaboration's database. The strategies used in the searches are included in Appendix D. The searches were augmented by a hand search of 10 ophthalmology- and anesthesia-related journals identified by the principal investigators as high priority, the reference lists of relevant review articles, and the reference lists of a sample of studies included in the literature review (Appendix E). Only Issue 1 of The Cochrane Library for 1999 was searched. Issue 2 of The Cochrane Library was due to be released in April but was not shipped until early in May 1999. The search included articles published through April 1999.

### Search Terms and Strategies

Medical subject heading (MeSH) terms used in the searches included cataract, anesthesia, and hypnotics or sedatives as both a MeSH heading and key word. For the PubMed searches, the basic search strategy was combined with an optimal search strategy for retrieving controlled trials (Robinson, Hinegardner, and Lansing, 1998). The MeSH term "case report" was added to the search strategy to allow the inclusion of case studies.

### Abstract Review

All search results were downloaded or hand entered into a database of studies that were considered potentially eligible for inclusion in the literature review. On a weekly basis, or as needed, the abstracts of all newly identified citations were independently reviewed by two members of the study team to determine if they met eligibility criteria. The abstract review form (Appendix F) was developed based on the abstract review form used in the Evidence Report on Management of New Onset Atrial Fibrillation (McNamara, Bass, Miller et al., 2001). All citations not meeting eligibility criteria were coded with the reason for exclusion. For those articles without an abstract or where a reviewer could not determine whether the abstract or citation met the eligibility criteria, a full copy of the article was retrieved and reviewed. Disagreements between reviewers about whether an abstract or citation should be included in the review were adjudicated at a meeting of the entire study team. The database, developed using ProCite software, was used to facilitate the tracking of search results, the abstract review process, and the printing of reports regarding identification of relevant literature.

In the review of abstracts, the emphasis was on sensitivity rather than specificity. The following criteria were used to exclude articles from further consideration:

- Addressed only general anesthesia.
- Did not address human data.
- Did not include adults.
- Was not written in English.
- Was a case series of fewer than 100 cases.
- Had no original data.

Reviewers of the abstract also identified which of the major questions each article principally addressed.

## Article Review

### Selection of Articles

Based on the results of the preliminary literature search (described above), we decided not to limit this systematic review to randomized clinical trials. We chose to include randomized clinical trials, nonrandomized controlled designs, and clinical series of 100 subjects or greater. Other eligibility criteria to be met for consideration of inclusion were relevance of the local anesthesia or sedation technique for practice in 1999 and clinical relevance of the assessed outcomes.

### Abstraction of Qualitative and Quantitative Data

We developed two data abstraction forms to allow consistent data abstraction of the relevant information from each study. The Quality Assessment Form is included as Appendix G and the Article Content Abstraction Form is included as Appendix H. The forms were pilot tested and revised extensively before final application to the published evidence.

The Quality Assessment Form was created based on the form used in the Evidence Report on Management of New Onset Atrial Fibrillation (McNamara, Bass, Miller et al., 2001). That form was developed through review of quality assessment forms used in meta-analytic studies performed by investigators of this Evidence-based Practice Center, review of the literature, and the assistance of the Cochrane Collaboration. Following pilot testing and revision, the Quality Assessment Form used in this evidence report contained 32 questions, which were grouped into domains as follows: (1) representativeness and patient selection -- how completely the authors described the study subjects; (2) bias and confounding, including completeness of description of randomization and masking (if applicable); (3) intervention description -- completeness of the description of the protocol and other treatments received (if applicable); (4) outcomes and followup, including explicit description of the outcomes reported (e.g., efficacy and complications of block and/or sedation/anesthesia) and the subjects' withdrawing; and (5) statistical quality and interpretation. Each question could earn a point value from 0 to 2. The score is the percentage of the total points available in each category. The overall quality score for each study is the average of its five categorical scores.

The Article Content Abstraction Form was developed through an iterative process of discussions among our study team and pilot testing on sample manuscripts. The form was used to abstract data pertinent to both questions under consideration for this evidence report. For pilot testing, each pair of reviewers reviewed two articles independently. The form was revised as needed. Instructions for the use of the form were developed by consensus for the purposes of consistency.

For assessment of regional anesthesia, the following elements were included:

- Description of the block (technique, location, personnel administering, agent, need for supplementation).
- Anesthesia outcomes (akinesia, patient assessment of pain and satisfaction, health care provider assessment of pain and satisfaction, anesthesia failure).

For assessment of patient sedation, the following elements were included:

- Intraoperative management (level of intraoperative monitoring, training of individual performing primary monitoring).
- Intraoperative planned analgesia (route of administration, agent, and dose).
- Outcomes of sedation (e.g., need for supplementation, patient recall during block/surgery, sedation score, anxiety score, hemodynamics).
- Complications of sedation (e.g., general anesthesia, supplemental ventilation, narcotic reversal, angina, arrhythmia, unplanned hospital admission).

Other elements included were:

- Patient demographics (age, gender, American Society of Anesthesia physical status classification, comorbidity).
- Surgical and ocular variables (operating room time, surgical techniques, surgical center characteristics).
- Surgical complications (e.g., lid ecchymosis, retrobulbar hemorrhage, nausea/vomiting, myocardial infarction, congestive heart failure, respiratory failure, hospitalization due to complications).

Each article was assigned a primary and secondary reviewer. At least one (and usually both) of the reviewers was an individual trained in research methodology and at least one (and usually both) were trained in ophthalmology, anesthesia, or internal medicine. For this project, three physicians in addition to the investigators named on the original project application, assisted in the review process: (1) John Kempen, M.D., M.P.H, an ophthalmologist trained in study methodology; (2) Jeffrey Magaziner, M.D., an internist and clinical scientist; and (3) Michael Sprintz, M.D., an anesthesiology resident.

The primary reviewer performed both the quality and content data abstraction and completed the relevant data abstraction forms. The secondary reviewer independently performed an assessment of study quality and then reviewed the data abstraction using the data abstraction forms completed by the primary reviewer. Differences between the reviewers were reconciled by the two raters in a conference to reach consensus. If a consensus could not be reached, one of the principal investigators served as a third reviewer to adjudicate the disagreement. The reviewers were not masked with regard to the author, institution, and journal.

All qualitative and quantitative data abstracted were entered into a computer database. This database was subsequently used for construction of evidence tables.

## Summary Evidence Tables

Three summary evidence tables (Evidence Tables 1, 2, and 3) were constructed to present data retrieved for overall description of the study, summary description of the intervention, and methodologic quality, respectively. A glossary of the abbreviations used in these tables precedes the evidence tables.

### Evidence Table 1: Overall Summary of Literature on Anesthesia for Cataract Surgery

This table includes information on the source of the article, study design, exclusion criteria used in the study, sample size (number of surgeries), principal outcomes reported, study limitations, overall quality score, and a bottom-line description of each study's results.

### Evidence Table 2: Summary of Interventions Reported in Literature on Anesthesia for Cataract Surgery

This table includes information on the source of the article, description of local anesthesia technique, anesthetic agents used in the local block, additional agents or techniques employed, volume and location of local anesthetic administered, whether a facial/lid block was performed, surgical technique, mean surgical time (in minutes), and sedating technique employed.

### Evidence Table 3: Methodologic Quality of Literature on Anesthesia for Cataract Surgery

This table includes information on the source of the article, exclusion criteria, scores on the individual quality scales, and the overall quality score.

The article abstraction forms were used to create a database using double data entry. The evidence tables were populated directly from the database. Subsequently, the accuracy of the evidence tables was assessed by comparison with the original articles and abstraction forms.

## Synthesis Tables

The synthesis of the data is based on the organization of the abstracted data around specific individual questions (Appendix I). For example, one of the suggested specific questions related to the efficacy of globe akinesia with different injection strategies. Manuscripts that provided information relative to this question were grouped together along with their principal results. A narrative description of the principal findings for each individual question is provided.

## Grading the Evidence

Evidence grades were assigned to the synthesis tables whenever a question involved the direct comparison of alternative techniques (e.g., intraoperative pain control with peribulbar versus retrobulbar anesthesia). The summary of the evidence for each table ends with a "conclusion" statement and the evidence grade. The evidence underlying the concluding statement was independently assessed by Drs. Schein, Fleisher, Friedman, and Bass. The method used to grade the evidence is based on a modification of the grading scheme employed by Garbutt, West, Carey et al. (1999) in their review of pharmacological treatment of alcohol dependence. The following schema was used in this project to grade the strength of the evidence:

Grade A (strong): Appropriate data are available for evaluating efficacy/safety of the interventions in question; overall, the population of patients studied is sufficiently large, and adequate controls have been used; data are consistent and indicate that the efficacy/safety of the intervention have been accurately described and that one intervention is clearly superior, equivalent, or inferior to another in terms of one or more well-defined outcomes.

Grade B (moderate): Appropriate data are available for evaluating safety/efficacy of the interventions in question; overall, the population of patients studied is sufficiently large; data are reasonably but not entirely consistent and indicate that the efficacy/safety of the intervention have been accurately described; the data indicate superiority (or equivalence) of one intervention over another for specific, well-defined outcomes; however, there is insufficient evidence to conclude definitively that the efficacy/safety of one intervention are clearly superior or inferior to another.

Grade C (weak): Some data are available for evaluating safety/efficacy of the interventions in question; overall, the population of patients studied is reasonably large; data indicate a trend supporting a benefit (or equivalence) of one intervention over another for specific, well-defined outcomes; however, there is insufficient evidence to conclude that one intervention is truly superior (or equivalent) to another.

Grade I (insufficient): Appropriate data are not available or an insufficient number of patients were studied to assess safety/efficacy of the intervention in question alone or in comparison to alternatives.

Whenever there was disagreement between the investigators as to the evidence grade, all of the evidence was simultaneously presented to the investigators and consensus achieved through discussion.

## Meta-analysis

Based upon our completed review of the literature (as described in the following section), the scientific assumptions that underlie justification for a meta-analysis were not met. Most importantly, the heterogeneity of the study aims, content, and design and the way in which the outcomes were measured precluded one's ability to pool the data in a meaningful or acceptable fashion.

## Supplemental Analyses

A full description of the methodology for the supplemental analyses completed for this evidence report may be found in the "Supplemental Analysis" section.

## Peer Review

A draft copy of the evidence report was sent to the core group of clinically oriented technical experts and peer review representatives of stakeholder organizations described above in "Recruitment of Experts." Through the use of a standardized form (Appendix J), we solicited reviewer opinion and comment on a number of issues related to the completeness, clarity, and presentation of the evidence. Comments were received from 12 of the 17 reviewers (71 percent). All comments were reviewed and discussed by the study team. Changes were made to the document in response to reviewers' comments, and a summary of the comments and responses was submitted to AHRQ.