# Introduction

## Background

Surgery for age-related cataract is the highest volume surgical condition in the Medicare population. Approximately 1.5 million cataract surgeries were performed on Medicare beneficiaries in 1996 (Steinberg, Javitt, Sharkey et al., 1993). For the past 15 years, cataract surgery in the United States has been performed almost exclusively as an outpatient procedure using a variety of local anesthetic techniques, typically in conjunction with systemic sedation.

Local analgesia for cataract surgery may be administered through either injection (peribulbar, retrobulbar, subconjunctival, etc.) or the use of topical anesthetic drops. Choice of local anesthesia technique is largely determined by surgeon preference. Complications that may rarely result from the use of local block anesthesia include orbital hemorrhage, globe perforation, and brain stem anesthesia (Davis and Mandel, 1986). The use of topical anesthesia eliminates the risk of these complications but may not provide complete anesthesia.

Preoperative and/or intraoperative sedation usually accompanies the use of injection techniques for local anesthesia and may be used with topical anesthesia. Anesthesiologist preferences and patient characteristics both influence the choice of sedating technique and agent. The use of these techniques is felt to reduce patient anxiety and decrease patient discomfort during local injection and surgery. However, patients undergoing surgery for age-related cataract often have comorbidities (e.g., heart disease, diabetes mellitus) that may impose a risk of complications related to sedation (e.g., perioperative hypertension, arrhythmia, myocardial ischemia) (Cataract Management Guideline Panel, 1993). The use of intraoperative sedation also requires the use of intraoperative monitoring of vital functions, although it is not clear what level of monitoring is adequate and which operating room personnel should act as monitors. There appears to be substantial variation, especially internationally, in the use of intravenous sedation and anesthesiologists/nurse anesthetists during cataract surgery. For example, in the United States and Canada, an anesthesiologist/nurse anesthetist is in attendance for virtually every case, whereas in Denmark, the presence of an anesthesiology professional during cataract surgery is exceptional (Norregaard, Schein, Bellan et al., 1997).

## Purpose of Evidence Report

The objectives of this evidence report are to: (1) identify the most important questions pertinent to anesthesia management for surgery for age-related cataract; (2) assess the published literature as to quality and content regarding these questions; and (3) inform practice and/or elucidate the need for future funded research, based on the literature findings.