# Appendix I. Questions for Literature Synthesis

## Specific Questions for Regional Anesthesia

1. Is there a difference between peribulbar and retrobulbar anesthetic block in achieving akinesia?
2. Is there a difference between retrobulbar and subconjunctival/sub-Tenon's anesthetic blocks in achieving akinesia?
3. Is there a difference between peribulbar and subconjunctival/sub-Tenon's anesthetic block in achieving akinesia?
4. Summary of the evidence regarding peribulbar injection and akinesia.
5. Summary of the evidence regarding retrobulbar anesthesia and akinesia.
6. Is there evidence of the effectiveness of a subconjunctival/sub-Tenon's block in producing akinesia?
7. Is there evidence that adding hyaluronidase to local blocks produces better akinesia than not adding hyaluronidase?
8. Is there evidence that certain anesthetic agents used in local blocks produce better akinesia?
9. Is there evidence that the volume of anesthetic used and speed of injection affect akinesia or pain during the block or surgery?
10. Is there evidence that the retrobulbar block technique is more or less painful than peribulbar block during administration of the block?
11. Is there evidence that retrobulbar block techniques are more painful for the patient while being administered than subconjunctival/sub-Tenon's block techniques?
12. Is there evidence that peribulbar techniques are more painful for the patient while being administered than subconjunctival/sub-Tenon's block techniques?
13. Summary of evidence on pain during administration of peribulbar block.
14. Summary of evidence regarding pain during administration of retrobulbar block.
15. Summary of evidence regarding pain during administration of subconjunctival/sub-Tenon's block.
16. Is there evidence that retrobulbar block is more or less painful for the patient during administration than topical block?
17. Is there evidence that peribulbar block is more or less painful for the patient during administration than topical block?
18. Is there evidence that subconjunctival/sub-Tenon's block is more or less painful for the patient during administration than topical block?
19. Is there evidence that retrobulbar block results in more or less pain than peribulbar block during cataract surgery?
20. Is there evidence that retrobulbar block results in more or less pain than subconjunctival/sub-Tenon's block during cataract surgery?
21. Is there evidence that peribulbar block results in more or less pain than subconjunctival/sub-Tenon's block during cataract surgery?
22. Summary of the evidence regarding pain during cataract surgery after peribulbar block.
23. Summary of the evidence regarding pain control during cataract surgery after retrobulbar block.
24. Summary of the evidence regarding pain during cataract surgery after subconjunctival/sub-Tenon's injection.
25. Is there evidence that retrobulbar block results in more or less pain during cataract surgery than topical block?
26. Is there evidence that peribulbar block results in more or less pain than topical block during cataract surgery?
27. Is there evidence that subconjunctival/sub-Tenon's block results in more or less pain during cataract surgery than topical anesthesia?
28. Summary of the evidence regarding pain during surgery after topical anesthesia.
29. Is there evidence that hyaluronidase added to the block decreases the pain experienced during the block?
30. Is there evidence that certain anesthetic agents used in local blocks produce better control of pain during cataract surgery?
31. Is there evidence that warming the anesthetic results in better akinesia, less pain during the block, or less pain during the operation than not warming the agents?
32. Is there evidence that raising the pH of the local anesthetic yields more effective or more comfortable local blocks?
33. Summary of the data on ocular and systemic complications reported with retrobulbar, peribulbar, subconjunctival/sub-Tenon's, and topical anesthesia.

## Specific Questions for Sedation Strategies

1. Is intravenous or intramuscular sedation superior to local anesthesia alone for pain control, patient cooperation, anxiety control, and patient satisfaction?
2. Summary of evidence on the effectiveness and safety of oral and intramuscular sedation.
3. Summary of the evidence on the effectiveness of intravenous sedation regarding patient cooperation, pain, anxiety, satisfaction, and medical and hemodynamic complications.
4. Is one class of sedative associated with improved outcome compared to another class?
5. Is patient-controlled analgesia safe and effective?