# Appendix H. Article Content Abstraction Form

EVIDENCE REPORT ON ANESTHESIA MANAGEMENT FOR CATARACT SURGERY ARTICLE CONTENT ASSESSMENT

1. Article ID__________________________________________.

2. First Author Name___________________________________.

3. Name of Primary Reviewer____________________________.

4. Name of Secondary Reviewer__________________________.

4a. Date of Review___________________________________.

## Regional Anesthesiaperibulbar Block

5. Peribulbar Block administered?..................... [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 14, page 7)

6. Details of block given?............................. [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 14, page 7)

7. Description of Peribulbar Block (indicate location and volume for all that apply):

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image]Infero-medial | [image]<4cc's [image]4-6cc's [image]>6cc's [image]can't tell
  [image]Supero-temporal | [image]<4cc's [image]4-6cc's [image]>6cc's [image]can't tell
  [image]Infero-temporal | [image]<4cc's [image]4-6cc's [image]>6cc's [image]can't tell
  [image]Trans-conjunctival | [image]<4cc's [image]4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

PERIBULBAR BLOCK NEEDLE

8. Peribulbar Block, Needle Length

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
[image]inches [image] mm [image] Can't Tell | [image]inches [image] mm [image] Can't Tell | [image]inches [image] mm [image] Can't Tell | [image]inches [image] mm [image] Can't Tell | [image]inches [image] mm [image] Can't Tell | [image]inches [image] mm [image] Can't Tell | [image]inches [image] mm [image] Can't Tell

9. Peribulbar Block, Needle Gauge

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
[image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell

10. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Peribulbar Block, Needle Tip | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified

11. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Peribulbar Block, Personnel Administering Block | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_______ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_______ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_______ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_______ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_______ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_______ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_______ [image] Can't Tell

12. PERIBULBAR BLOCK, ANESTHETIC AGENTS (for each agent used, indicate concentration and volume).

12A. Bupivacaine (Marcaine, Sensorcaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

12B. Etidocaine (Duranest) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

12C. Lidocaine (Lignocaine, Xylocaine, Ultracaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

12D. Mepivicaine (Carbocaine, Polocaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

12E. Prilocaine | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

12F. Procaine (Novocaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

12G. Peribulbar Block Other Anesthesia Agents: (specify) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume

12H. Peribulbar Block Other Anesthesia Agents: (specify) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume

12I. Peribulbar Block Other Anesthesia Agents: (specify) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume

13.

Peribulbar Block, Comments:

## Retrobulbar Block

14. Retrobulbar Block administered? ..................... [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 23, page 12)

15. Details of block given? ............................. [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 23, page 12)

16. Description of Retrobulbar Block (indicate location and volume for all that apply):

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image]Infero-medial | [image]<4cc's [image]4-6cc's [image]>6cc's [image]can't tell
  [image]Supero-temporal | [image]<4cc's [image]4-6cc's [image]>6cc's [image]can't tell
  [image]Infero-temporal | [image]<4cc's [image]4-6cc's [image]>6cc's [image]can't tell
  [image]Trans-conjunctival | [image]<4cc's [image]4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  LOCATION | VOLUME
  [image] Supero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-medial | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Supero-temporal | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Infero-temporal | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Trans-conjunctival | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell
  [image] Can't Tell | [image] <4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

RETROBULBAR BLOCK NEEDLE

17. Retrobulbar Block, Needle Length

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
______[image]inches [image] mm [image] Can't Tell | ______[image]inches [image] mm [image] Can't Tell | ______[image]inches [image] mm [image] Can't Tell | ______[image]inches [image] mm [image] Can't Tell | ______[image]inches [image] mm [image] Can't Tell | ______[image]inches [image] mm [image] Can't Tell | ______[image]inches [image] mm [image] Can't Tell

18. Retrobulbar Block, Needle Gauge

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
[image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image]30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell | [image] 30 (0.3mm) [image] 27 (0.4mm) [image] 25 (0.5mm) [image] Other/Specify _____________ [image] Can't Tell

19. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Retrobulbar Block, Needle Tip | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified | [image]Sharp [image] Blunt [image] Not Specified

20. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Retrobulbar Block, Personnel Administering Block | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_________ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_________ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_________ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_________ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_________ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_________ [image] Can't Tell | [image]Surgeon [image] Anesthesiologist [image] CRNA [image] Other_________ [image] Can't Tell

21A. RETROBULBAR BLOCK, ANESTHETIC AGENTS (for each agent used, indicate concentration and volume).

21A. Bupivacaine (Marcaine, Sensorcaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

21B. Etidocaine (Duranest) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

21C. Lidocaine (Lignocaine, Xylocaine, Ultracaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

21D. Mepivicaine (Carbocaine, Polocaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

21E. Prilocaine | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

21F. Procaine (Novocaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

21G. Other | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume

21H. Other | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume

21I. Other | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration
Volume

22.

Retrobulbar Block, Comments:

## Subconjunctival and/or Sub-Tenon's Local Block

23. Subconjunctival or Sub-Tenon's local block used? ............. [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 28, page 14)

24. Details of block given? ...................................... [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 28, page 14)

25.

Description of Subconjunctival or Sub-Tenon's Block | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Cannula Gauge
Needle Gauge | [image]30 (0.3mm) [image] 27 (0.4mm) [image]25 (0.5mm) [image]Other ___________ | [image]30 (0.3mm) [image] 27 (0.4mm) [image]25 (0.5mm) [image]Other __________ | [image]30 (0.3mm) [image] 27 (0.4mm) [image]25 (0.5mm) [image]Other ___________ | [image]30 (0.3mm) [image] 27 (0.4mm) [image]25 (0.5mm) [image]Other ___________ | [image]30 (0.3mm) [image] 27 (0.4mm) [image]25 (0.5mm) [image]Other __________ | [image]30 (0.3mm) [image] 27 (0.4mm) [image]25 (0.5mm) [image]Other __________ | [image]30 (0.3mm) [image] 27 (0.4mm) [image]25 (0.5mm) [image]Other __________
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

26. SUBCONJUNCTIVAL/SUB-TENON'S BLOCK, ANESTHETIC AGENTS (for each agent used, indicate volume).

26A. Bupivacaine (Marcaine, Sensorcaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

26B. Etidocaine (Duranest) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

26C. Lidocaine (Lignocaine, Xylocaine, Ultracaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

26D. Mepivicaine (Carbocaine, Polocaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

26E. Prilocaine | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

26F. Procaine (Novocaine) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

26G. Other Anesthetic Agent (specify) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

26H. Other Anesthetic Agent (specify) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

26I. Other Anesthetic Agent (specify) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

27.

Subconjunctival or Sub-Tenon's Block, Comments:

28. Lid Block/Facial Nerve Block

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
[image]Yes [image] No [image] Can't Tell | [image]Yes [image] No [image] Can't Tell | [image]Yes [image] No [image] Can't Tell | [image]Yes [image] No [image] Can't Tell | [image]Yes [image] No [image] Can't Tell | [image]Yes [image] No [image] Can't Tell | [image]Yes [image] No [image] Can't Tell

## ADDITIONAL AGENTS FOR LOCAL BLOCK ANESTHESIA

29. Study design included use of additional agents: | Clonidine...........................[image] Yes..........[image] No .........[image] Can't Tell
| Epinephrine......................[image] Yes..........[image] No .........[image] Can't Tell
| Hyaluronidase...................[image] Yes..........[image] No .........[image] Can't Tell
| Other..................................[image] Yes..........[image] No .........[image] Can't Tell _______________________________

29A. Clonidine | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Concentration | [image]0.5% [image] 1.0% [image] 2.0% | [image]0.5% [image] 1.0% [image] 2.0% | [image]0.5% [image] 1.0% [image] 2.0% | [image]0.5% [image] 1.0% [image] 2.0% | [image]0.5% [image] 1.0% [image] 2.0% | [image]0.5% [image] 1.0% [image] 2.0% | [image]0.5% [image] 1.0% [image] 2.0%
Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

29B. Epinephrine | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Agent Used? | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No

29C. Hyaluronidase (Wydase) | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Agent Used? | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No

29D. Other | | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Agent ______________________
Agent ______________________ | Concentration
| Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

29E. Other | | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Agent ______________________
Agent ______________________ | Concentration
| Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

29F. Other | | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Agent ______________________
Agent ______________________ | Concentration
| Volume | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell | [image]<4cc's [image] 4-6cc's [image] >6cc's [image] can't tell

30.

Additional Local Agents Comments:

31. Study uses additional techniques for local block ........... [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 33, page 18)

31A. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Warming of Anesthesia Agents
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No

31B. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
pH Buffering
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No
  [image]Yes | [image]No

31C. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Injection Speed
  [image]Fast | [image]Slow
  [image]Fast | [image]Slow
  [image]Fast | [image]Slow
  [image]Fast | [image]Slow
  [image]Fast | [image]Slow
  [image]Fast | [image]Slow
  [image]Fast | [image]Slow

31D. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Injection Pressure
  [image]High | [image]Low
  [image]High | [image]Low
  [image]High | [image]Low
  [image]High | [image]Low
  [image]High | [image]Low
  [image]High | [image]Low
  [image]High | [image]Low

31E. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Other(specify)_____________________

32.

Comments on Additional Techniques:

## Topical Anesthesia

33. Study design included topical anesthesia ...................... [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 38, page 20)

34. Details of topical anesthesia given........ [image] Yes .......[image] No

35. Topical Anesthesia Agents: Complete, as indicated, for all agents listed.

| GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
35A. EMLA | [image]Yes | [image]Yes | [image]Yes | [image]Yes | [image]Yes | [image]Yes | [image]Yes
35B. Lidocaine Gel | [image]1% [image] 2% [image] 4% | [image]1% [image] 2% [image] 4% | [image]1% [image] 2% [image] 4% | [image]1% [image] 2% [image] 4% | [image]1% [image] 2% [image] 4% | [image]1% [image] 2% [image] 4% | [image]1% [image] 2% [image] 4%
35C. Proparacaine | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops
35D. Tetracaine | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops
35E. Other Topical Agent (specify) | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops
35F. Other Topical Agent (specify) | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops
35G. Other Topical Agent (specify) | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops | ______% ______Total Drops

36.

Intracameral Lidocaine | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
| [image]0.5% [image]1.0% [image]2.0% | [image]0.5% [image]1.0% [image]2.0% | [image]0.5% [image]1.0% [image]2.0% | [image]0.5% [image]1.0% [image]2.0% | [image]0.5% [image]1.0% [image]2.0% | [image]0.5% [image]1.0% [image]2.0% | [image]0.5% [image]1.0% [image]2.0%

37.

Topical Anesthesia Comments:

## Planned Sedation

38. Study design included planned sedation ................. [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 42, page 22)

39. Route of administration. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
| [image]IV [image] PCA [image] ORAL [image] IM [image] Other, Specify ______________ | [image]IV [image] PCA [image] ORAL [image] IM [image] Other, Specify ______________ | [image]IV [image] PCA [image] ORAL [image] IM [image] Other, Specify ______________ | [image]IV [image] PCA [image] ORAL [image] IM [image] Other, Specify ______________ | [image]IV [image] PCA [image] ORAL [image] IM [image] Other, Specify ______________ | [image]IV [image] PCA [image] ORAL [image] IM [image] Other,Specify ______________ | [image]IV [image] PCA [image] ORAL [image] IM [image] Other, Specify ______________

## Preoperative Oral Medication

40. Agent and Dose (for each agent, indicate mean total dose).

| GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
40A. Oral Diazepam (Valium) Mean Total Dose | [image]<5.0mg [image] 6-10 mg [image] >10mg [image] can't tell | [image]<5.0mg [image] 6-10 mg [image] >10mg [image] can't tell | [image]<5.0mg [image] 6-10 mg [image] >10mg [image] can't tell | [image]<5.0mg [image] 6-10 mg [image] >10mg [image] can't tell | [image]<5.0mg [image] 6-10 mg [image] >10mg [image] can't tell | [image]<5.0mg [image] 6-10 mg [image] >10mg [image] can't tell | [image]<5.0mg [image] 6-10 mg [image] >10mg [image] can't tell
40B. Benadryl Mean Total Dose | [image]<25mg [image] 26-50mg [image] >50mg [image] can't tell | [image]<25mg [image] 26-50mg [image] >50mg [image] can't tell | [image]<25mg [image] 26-50mg [image] >50mg [image] can't tell | [image]<25mg [image] 26-50mg [image] >50mg [image] can't tell | [image]<25mg [image] 26-50mg [image] >50mg [image] can't tell | [image]<25mg [image] 26-50mg [image] >50mg [image] can't tell | [image]<25mg [image] 26-50mg [image] >50mg [image] can't tell
40C. Clonidine Mean Total Dose | [image]0.1mg [image] 0.2mg [image] 0.3mg [image] can't tell | [image]0.1mg [image] 0.2mg [image] 0.3mg [image] can't tell | [image]0.1mg [image] 0.2mg [image] 0.3mg [image] can't tell | [image]0.1mg [image] 0.2mg [image] 0.3mg [image] can't tell | [image]0.1mg [image] 0.2mg [image] 0.3mg [image] can't tell | [image]0.1mg [image] 0.2mg [image] 0.3mg [image] can't tell | [image]0.1mg [image] 0.2mg [image] 0.3mg [image] can't tell
40D. Lorazepam Mean Total Dose | [image]<1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]<1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]<1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]<1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]<1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]<1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]<1mg [image] 1.1-2mg [image] >2mg [image] can't tell
40E. Other Oral Preoperative Medication(Specify):_______________________ Mean Total Dose
40F. Other Oral Preoperative Medication (specify):_______________________ Mean Total Dose
40G. Other Oral Preoperative Medication (specify):_______________________ Mean Total Dose

41.

Preoperative Oral Medication Comments:

## Planned Intravenous or Intramuscular Medication

42. Study design included use of planned intravenous or intramuscular sedation.......................... [image] Yes ..... [image] No ..... [image] Can't Tell → (If No, or Can't Tell Go To Question 48, page 26)

## Sedatives

Intravenous or Intramuscular Medications Used, for each agent used, indicate total dose.

43. BENZODIAZEPINES

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
43B. Diazepam (Valium) Mean Total Dose | [image]< 5mg [image] 5-9.9mg [image]> 10mg [image] can't tell | [image]< 5mg [image] 5-9.9mg [image]> 10mg [image] can't tell | [image]< 5mg [image] 5-9.9mg [image]> 10mg [image] can't tell | [image]< 5mg [image] 5-9.9mg [image]> 10mg [image] can't tell | [image]< 5mg [image] 5-9.9mg [image]> 10mg [image] can't tell | [image]< 5mg [image] 5-9.9mg [image]> 10mg [image] can't tell | [image]< 5mg [image] 5-9.9mg [image]> 10mg [image] can't tell
43C. Lorazepam (Ativan) Mean Total Dose | [image]< 1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]< 1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]< 1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]< 1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]< 1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]< 1mg [image] 1.1-2mg [image] >2mg [image] can't tell | [image]< 1mg [image] 1.1-2mg [image] >2mg [image] can't tell
43D. Midazolam (Versed) Mean Total Dose | [image]< 2mg [image] 2.1-5mg [image] >5mg [image] can't tell | [image]< 2mg [image] 2.1-5mg [image] >5mg [image] can't tell | [image]< 2mg [image] 2.1-5mg [image] >5mg [image] can't tell | [image]< 2mg [image] 2.1-5mg [image] >5mg [image] can't tell | [image]< 2mg [image] 2.1-5mg [image] >5mg [image] can't tell | [image]< 2mg [image] 2.1-5mg [image] >5mg [image] can't tell | [image]<2mg [image] 2.1-5mg [image] >5mg [image] can't tell
43E. Other Benzodiazepines: (specify) | ________ mg | ________ mg | ________ mg | ________ mg | ________ mg | ________ mg | ________ mg
43F. Other Benzodiazepines: (specify) | ________ mg | ________ mg | ________ mg | ________ mg | ________ mg | ________ mg | ________ mg

44. BARBITURATES

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
44A. Methohexital (Brevital) Mean Total Dose | [image]< 50mg [image] >50mg [image] can't tell | [image]< 50mg [image] >50mg [image] can't tell | [image]< 50mg [image] >50mg [image] can't tell | [image]< 50mg [image] >50mg [image] can't tell | [image]< 50mg [image] >50mg [image] can't tell | [image]< 50mg [image] >50mg [image] can't tell | [image]< 50mg [image] >50mg [image] can't tell
44B. Thiopentothal (Pentothal) Mean Total Dose | __________mg | __________mg | __________mg | __________mg | __________mg | __________mg | __________mg
44C. Other Barbiturates: (specify) Mean Total Dose | __________mg | __________mg | __________mg | __________mg | __________mg | __________mg | __________mg
44D. Other Barbiturates: (specify) Mean Total Dose | __________mg | __________mg | __________mg | __________mg | __________mg | __________mg | __________mg

45. ANALGESICS

| GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
45A. Alfentanyl (Alfenta) Mean Total Dose | [image]< 500 mcg [image] > 500 mcg | [image]< 500 mcg [image] > 500 mcg | [image]< 500 mcg [image] > 500 mcg | [image]< 500 mcg [image] > 500 mcg | [image]< 500 mcg [image] > 500 mcg | [image]< 500 mcg [image] > 500 mcg | [image]< 500 mcg [image] > 500 mcg
45B. Fentanyl (Sublimaze) Mean Total Dose | [image]< 100 mcg [image] 101-250 mcg [image] > 250 mcg | [image]< 100 mcg [image] 101-250 mcg [image] > 250 mcg | [image]< 100 mcg [image] 101-250 mcg [image] > 250 mcg | [image]< 100 mcg [image] 101-250 mcg [image] > 250 mcg | [image]< 100 mcg [image] 101-250 mcg [image] > 250 mcg | [image]< 100 mcg [image] 101-250 mcg [image] > 250 mcg | [image]< 100 mcg [image] 101-250 mcg [image] > 250 mcg
45C. Ketorolac (Toradol) Mean Total Dose | [image] 30mg_______ [image] 60mg_______ | [image] 30mg_______ [image] 60mg_______ | [image] 30mg_______ [image] 60mg_______ | [image] 30mg_______ [image] 60mg_______ | [image] 30mg_______ [image] 60mg_______ | [image] 30mg_______ [image] 60mg_______ | [image] 30mg_______ [image] 60mg_______
45D. Morphine (Roxanol) Mean Total Dose | [image] < 5mg [image] 5-10mg | [image] < 5mg [image] 5-10mg | [image] < 5mg [image] 5-10mg | [image] < 5mg [image] 5-10mg | [image] < 5mg [image] 5-10mg | [image] < 5mg [image] 5-10mg | [image] < 5mg [image] 5-10mg
45E. Propofol (Diprivan) Mean Total Dose | [image]< 100mg [image] 101-200mg [image] 200mg | [image]< 100mg [image] 101-200mg [image] 200mg | [image]< 100mg [image] 101-200mg [image] 200mg | [image]< 100mg [image] 101-200mg [image] 200mg | [image]< 100mg [image] 101-200mg [image] 200mg | [image]< 100mg [image] 101-200mg [image] 200mg | [image]< 100mg [image] 101-200mg [image] 200mg
45F. Other Analgesics: (specify) Mean Total Dose
45G. Other Analgesics: (specify) Mean Total Dose

46. Other Intravenous Medications

| GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
46A. Clonidine (Catapres, Combipress, Duralion) Mean Total Dose | [image]0.1mg [image] 0.2mg [image] 0.3mg | [image]0.1mg [image] 0.2mg [image] 0.3mg | [image]0.1mg [image] 0.2mg [image] 0.3mg | [image]0.1mg [image] 0.2mg [image] 0.3mg | [image]0.1mg [image] 0.2mg [image] 0.3mg | [image]0.1mg [image] 0.2mg [image] 0.3mg | [image]0.1mg [image] 0.2mg [image] 0.3mg
46B. Diphenhydramine (Benadryl) Mean Total Dose | [image]< 25mg [image] 25-50mg [image] > 50mg | [image]< 25mg [image] 25-50mg [image] > 50mg | [image]< 25mg [image] 25-50mg [image] > 50mg | [image]< 25mg [image] 25-50mg [image] > 50mg | [image]< 25mg [image] 25-50mg [image] > 50mg | [image]< 25mg [image] 25-50mg [image] > 50mg | [image]< 25mg [image] 25-50mg [image] > 50mg
46C. Clorazepate -Dipotassium (Tranxene,Gen-xene) Mean Total Dose | [image]3.75mg [image] 7.5mg | [image]3.75mg [image] 7.5mg | [image]3.75mg [image] 7.5mg | [image]3.75mg [image] 7.5mg | [image]3.75mg [image] 7.5mg | [image]3.75mg [image] 7.5mg | [image]3.75mg [image] 7.5mg
46D. Droperidol Mean Total Dose | [image]0.625 mg [image] 1.75 mg [image]> 2.5 mg | [image]0.625 mg [image] 1.75 mg [image]> 2.5 mg | [image]0.625 mg [image] 1.75 mg [image]> 2.5 mg | [image]0.625 mg [image] 1.75 mg [image]> 2.5 mg | [image]0.625 mg [image] 1.75 mg [image]> 2.5 mg | [image]0.625 mg [image] 1.75 mg [image]> 2.5 mg | [image]0.625 mg [image] 1.75 mg [image]> 2.5 mg
46E. Ondansetron (Zofran) Mean Total Dose | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No | [image]Yes [image] No
46F. Promazine Mean Total Dose
46G. Saline Placebo | [image]Yes | [image]Yes | [image]Yes | [image]Yes | [image]Yes | [image]Yes | [image]Yes
46H. Other Mean Total Dose
46I. Other Mean Total Dose
46J. Other Mean Total Dose

47.

Intravenous Medication Comments:

## Unplanned Sedation

48. Was unplanned sedation used?................. [image] Yes [image] No [image] Can't Tell (If No or Can't Tell go to Question 50, page 27)

48a. For each agent used, indicate number of patients receiving agent in each group.

| GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
49A. Unplanned, Supplemental Benzodiazepines
49B. Unplanned, Supplemental Barbiturates
49C. Unplanned, Supplemental Propofol
49D. Unplanned, Supplemental Benadryl
49E. Other ________________
49F. Unplanned, Supplemental Analgesics (specify)
49G. Unplanned, Supplemental Anti-emetics (specify)

49H.

Unplanned Sedation Comments:

## SUPPLEMENTAL INTERVENTIONS TO CALM THE PATIENT (e.g., music, prayer)

50. Did study design include any supplemental interventions? ......... [image] Yes........ [image] No...... [image] Can't Tell (If No or Can't Tell go to Question 52, page 28) If yes, specify intervention received by group.

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G

51.

Supplemental Interventions Comments:

## BASELINE PATIENT DEMOGRAPHICS

52. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
52A. Number of subjects
52B. Age (mean)
52C. Number of eyes
52D. Number of male subjects
52E. Number of white subjects
52F. Number of subjects with diabetes
52G. Number of smokers
52H. Number of subjects with hypertension
52I. Number of subjects with CAD
52J. Number of subjects with CHF
52K. Number of subjects with COPD
52L. Mean ASA score
52M. Median ASA score
52N. Number of subjects with ASA score > 3
52O. Other comorbidity index

52P.

Baseline Patient Demographics Comments:

## Intraoperative Monitoring

53. Monitoring Used

53A. Electrocardiogram ............................. [image]Yes..... [image]No...... [image]Can't Tell

53B. ST Segment Monitoring .....................[image]Yes..... [image]No...... [image]Can't Tell

53C. Blood Pressure ...................................... [image]Yes...... [image]No....... [image]Can't Tell

53D. Oxygen Saturation .............................. [image]Yes..... [image]No...... [image]Can't Tell

53E. End-tidal Carbon Dioxide .................. [image]Yes..... [image]No...... [image]Can't Tell

53F. Respiratory Rate ................................. [image]Yes..... [image]No...... [image]Can't Tell

54. Primary Monitoring Individual (check one)

Anesthesiologist................... [image]

CRNA .................................. [image]

RN ....................................... [image]

PA ......................................... [image]

Ophthalmologist .............. [image]

No One ................................ [image]

Can't Tell ............................ [image]

55. Country in which study performed (specify):_____________________________________________________________

56. Specify location of surgery:

[image] Free Standing ASC

[image] Hospital

[image] Office

[image] Can't Tell

57. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Routine Supplemental Oxygen | [image] Yes [image] No [image] Can't Tell | [image] Yes [image] No [image] Can't Tell | [image] Yes [image] No [image] Can't Tell | [image] Yes [image] No [image] Can't Tell | [image] Yes [image] No [image] Can't Tell | [image] Yes [image] No [image] Can't Tell | [image] Yes [image] No [image] Can't Tell

## REGIONAL/LOCAL BLOCK ANESTHESIA OUTCOMES SURGICAL AND OCULAR VARIABLES

58. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
OR Time in minutes (also includes total operative time) | Mean__________ Median_________ | Mean__________ Median_________ | Mean__________ Median_________ | Mean__________ Median_________ | Mean__________ Median_________ | Mean__________ Median_________ | Mean__________ Median_________

59. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Surgical Time in minutes | Mean___________ Median___________ | Mean___________ Median___________ | Mean___________ Median___________ | Mean___________ Median___________ | Mean___________ Median___________ | Mean___________ Median___________ | Mean___________ Median___________

60. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Predominant Surgical Technique (check one only) | [image] PE [image] PE Clear Cornea [image] ECCE [image] ICCE [image] Can't Tell | [image] PE [image] PE Clear Cornea [image] ECCE [image] ICCE [image] Can't Tell | [image] PE [image] PE Clear Cornea [image] ECCE [image] ICCE [image] Can't Tell | [image] PE [image] PE Clear Cornea [image] ECCE [image] ICCE [image] Can't Tell | [image] PE [image] PE Clear Cornea [image] ECCE [image] ICCE [image] Can't Tell | [image] PE [image] PE Clear Cornea [image] ECCE [image] ICCE [image] Can't Tell | [image] PE [image] PE Clear Cornea [image] ECCE [image] ICCE [image] Can't Tell

61. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Axial Length | Number >25mm__________ | Number >25mm__________ | Number >25mm__________ | Number >25mm__________ | Number >25mm__________ | Number >25mm__________ | Number >25mm__________

## OUTCOMES OF REGIONAL ANESTHESIA

62. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Assessment of Akinesia During Surgery (number of patients) | Complete________ Moderate________ Poor__________ Can't Tell [image] | Complete________ Moderate________ Poor__________ Can't Tell [image] | Complete________ Moderate________ Poor__________ Can't Tell [image] | Complete________ Moderate________ Poor__________ Can't Tell [image] | Complete________ Moderate________ Poor__________ Can't Tell [image] | Complete________ Moderate________ Poor__________ Can't Tell [image] | Complete________ Moderate________ Poor__________ Can't Tell [image]

63.

Comments on Akinesia During Surgery:

## COMPLICATIONS OF REGIONAL ANESTHESIA

64. Were complications of regional anesthesia reported? ..................... [image] Yes ..... [image] No → (If No, Go To Question 76, page 33)

65. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Supplemental Regional Anesthesia Given (number of patients receiving) | [image] Drops_____ [image] Sub-conjunctival_____ [image] Sub-Tenon's_____ [image] Peribulbar_____ [image] Retrobulbar_____ [image] Can't Tell_____ | [image] Drops_____ [image] Sub-conjunctival_____ [image] Sub-Tenon's_____ [image] Peribulbar_____ [image] Retrobulbar_____ [image] Can't Tell_____ | [image] Drops_____ [image] Sub-conjunctival_____ [image] Sub-Tenon's_____ [image] Peribulbar_____ [image] Retrobulbar_____ [image] Can't Tell_____ | [image] Drops_____ [image] Sub-conjunctival_____ [image] Sub-Tenon's_____ [image] Peribulbar_____ [image] Retrobulbar_____ [image] Can't Tell_____ | [image] Drops_____ [image] Sub-conjunctival_____ [image] Sub-Tenon's_____ [image] Peribulbar_____ [image] Retrobulbar_____ [image] Can't Tell_____ | [image] Drops_____ [image] Sub-conjunctival_____ [image] Sub-Tenon's_____ [image] Peribulbar_____ [image] Retrobulbar_____ [image] Can't Tell_____ | [image] Drops_____ [image] Sub-conjunctival_____ [image] Sub-Tenon's_____ [image] Peribulbar_____ [image] Retrobulbar_____ [image] Can't Tell_____

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
  66. | Retrobulbar Hemorrhage (number of patients)
  67. | Ruptured Globe (number of patients)
  68. | Brainstem Anesthesia (number of patients)

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
  69. | PC Rupture and/or Vitrectomy (number of patients)
  70. | Strabismus (number of patients)
  71. | Ptosis (number of patients)
  72. | Other Complications: (specify)
  73. | Other Complications: (specify)
  74. | Other Complications: (specify)

75.

COMPLICATIONS OF REGIONAL ANESTHESIA

Comments on Supplemental Regional Anesthesia:

## HEALTH CARE PROFESSIONAL ASSESSMENT OF PAIN AND COOPERATION

76. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Surgeon Assessment of adequate cooperation (number of patients)

77. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Anesthesiologist/Observer assessment of adequate cooperation (number of patients)

78. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Assessment of Physician Satisfaction with the pain management technique (number of patients) | Excellent __________ Very Good _________ Good___________ Fair _______________ Poor ______________ | Excellent __________ Very Good _________ Good___________ Fair _______________ Poor ______________ | Excellent __________ Very Good _________ Good___________ Fair _______________ Poor ______________ | Excellent __________ Very Good _________ Good___________ Fair _______________ Poor ______________ | Excellent __________ Very Good _________ Good__________ Fair ________________ Poor ______________ | Excellent __________ Very Good _________ Good__________ Fair ________________ Poor ______________ | Excellent __________ Very Good _________ Good___________ Fair _______________ Poor ______________

79.

Comments on Assessment of Physician Satisfaction:

## Patient Pain and Satisfaction

80. The Block

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Recall of Block (at time of first measurement) (number of patients)
Pain During Block (10 point scale) | None 0 _________ Mild 1-2 ________ Moderate 3-5 ____ Severe >5 _______ | None 0 _________ Mild 1-2 ________ Moderate 3-5 ____ Severe >5 _______ | None 0 _________ Mild 1-2 ________ Moderate 3-5 ____ Severe >5 _______ | None 0 _________ Mild 1-2 ________ Moderate 3-5 ____ Severe >5 _______ | None 0 _________ Mild 1-2 ________ Moderate 3-5 ____ Severe >5 _______ | None 0 _________ Mild 1-2 ________ Moderate 3-5 ____ Severe >5 _______ | None 0 _________ Mild 1-2 ________ Moderate 3-5 ____ Severe >5 _______
Pain During Block (mean)
Pain During Block (median)

81. Surgical Pain

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Recall of Surgery (at time of first measurement) (number of patients)
Pain During Surgery (10 point scale) | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5_____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______
Surgical Pain: Post-op day of surgery (10 point scale), (first measurement) | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______
Surgical Pain: measured post-op 1 day post surgery (10 point scale) | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5__ Severe >5 _____ Mean ________ Median _______

82. Postoperative Pain

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Postoperative Pain (number of patients)
Post-op Pain on day of surgery (10 point scale) (first measurement) | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______
Post-op Pain measured > 1 day post surgery (10 point scale) | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______ | None 0 _______ Mild 1-2 ______ Moderate 3-5 __ Severe >5 _____ Mean ________ Median _______

83. Pain Assessment Technique ........... | [image] VAS _________________Low Anchor, _____________High Anchor
| [image]Ordinal _________________Low Anchor, __________High Anchor
| [image]Other (specify)__________________________________________

84.

Comments on Pain Assessment:

85. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Anxiety Assessment (number of patients) | None 0______ Mild 1-2______ Moderate 3-5______ Severe >5______ Mean______ Median______ | None 0______ Mild 1-2______ Moderate 3-5______ Severe >5______ Mean______ Median______ | None 0______ Mild 1-2______ Moderate 3-5______ Severe >5______ Mean______ Median______ | None 0______ Mild 1-2______ Moderate 3-5______ Severe >5______ Mean______ Median______ | None 0______ Mild 1-2______ Moderate 3-5______ Severe >5______ Mean______ Median______ | None 0______ Mild 1-2______ Moderate 3-5______ Severe >5______ Mean______ Median______ | None 0______ Mild 1-2______ Moderate 3-5______ Severe >5______ Mean______ Median______

86. Anxiety Assessment Technique ........ | [image] VAS _______________Low Anchor,_______________High Anchor
| [image]Ordinal_____________Low Anchor,_______________High Anchor
| [image]Other (specify)_________________________________________

87.

Comments on Anxiety Assessment Technique:

88. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Patient satisfaction with anesthesia management assessed immediate post-op (number of patients) | Excellent_______ Very Good_______ Good_______ Fair_______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______

89.

Comments on Patient Satisfaction Assessment (immediate):

90. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Patient satisfaction with anesthesia management assessed one or more days post-op (number of patients) | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______ | Excellent _______ Very Good _______ Good_______ Fair _______ Poor_______

91.

Comments on Patient Satisfaction Assessment (1+ days postop):

92. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Patient desires management strategy again (number of patients)

93.

Comments on Patient Pain and Satisfaction Assessment:

## Adverse Medical Outcomes

94. Medical Outcomes Reported?....................................... [image] Yes ..... [image] No → (If No, Go To Question 96, page 40) For each, record number of patients in each group.

GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
94A. Myocardial Infarction
94B. New or Worsened CHF
  94C. | Ventricular Arrhythmia
  94D. | Other Non-Sinus Arrhythmia
94E. Stroke
94F. TIA
94G. Respiratory Failure
  94H. | Hospitalization due to complications

95.

Adverse Medical Outcomes Comments:

## Complications of Sedation

Complications of sedation reported? ................................ [image] Yes ..... [image] No → (If No, Go To Question 98, page 41) For each, record number of patients.

| GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
  96A. | Number converted to General Anesthesia
  96B. | Number Ventilated with Bag and Mask
  96C. | Endotracheal Intubation
  96D. | Narcotic Reversal: Narcan, Naloxane
  96E. | Flumazenil: Benzodiazepine Reversal
  96F. | Ischemic Event
96G. Cardioversion
96H. CPR
96I. Seizure

97.

Complications of Sedation Comments:

## Recovery Characteristics

98. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Psychomotor Scores (number of patients) | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________

99. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Patient Readiness for Discharge | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________ | Immediate < 60 minutes________ Delayed > 60 minutes________

100. | GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
Nausea/Vomiting (number of patients)

101.

Recovery Characteristics Comments:

## Hemodynamics

102. Hemodynamics Reported?.......... [image] Yes.......... [image] No

| GROUP A | GROUP B | GROUP C | GROUP D | GROUP E | GROUP F | GROUP G
  102A. | Number of Patients Treated for Hypertension
  102B. | Number with Heart Rate > 100 bpm (number of patients)
  102C. | Number Treated for Tachycardia (number of patients)
  102D. | Number Treated for Bradycardia (number of patients)
  102E. | Sp02 (Sa02 < 90%) (number of patients)

103.

Comments on Hemodynamics:

104.

Bottom Line Based on Article Assessment:

105. Local and IV analgesia is superior, to a clinically significant degree, to local alone? ..... [image] Supports ... [image] Refutes .... [image] No Data/Doesn't Address

106. Use of IV sedation is superior, to a clinically significant degree, to not using IV sedation for:

a. Patient pain anxiety and satisfaction..................... [image] Supports ... [image] Refutes ... [image] No Data/Doesn't Address
b. Effect on patient physiology (metabolic or hemodynamics)...................... [image] Supports ... [image] Refutes ... [image] No Data/Doesn't Address
c. Effect on patient outcomes.............................. [image] Supports ... [image] Refutes ... [image] No Data/Doesn't Address