# Appendix G. Article Quality Assessment Form

OPHTHALMIC ANESTHESIA LITERATURE REVIEW

QUALITY ASSESSMENT FORM

1. Article ID number: _______________________________________

2. First author: ____________________________________________

3a. Primary Reviewer:_______________________________________

3b. Secondary Reviewer:_____________________________________

1. Date of review:_____________________________
2. BASIC FEATURES (circle if answer is true, circle only one):
  a. did NOT address human data
  b. did NOT address anesthesia management for cataract surgery
  c. did NOT report data separately for cataract surgery
  d. ONLY addressed general anesthesia
  e. adults are NOT part of the population
  f. NO original data
  g. was NOT controlled trial or case series > 100 patients
  h. meeting abstract
  i. data not presented in an abstractable format
  IF ANY OF THE ABOVE ITEMS IS CIRCLED -- STOP
3. Are outcomes assessed in article the clinically relevant ones.?................................................... [image]Yes......... No
4. For articles focusing on regional or topical anesthesia, is the technique assessed in article relevant to 1999?................................................................ [image]Yes ....... No
5. For articles focusing on sedation, is the technique assessed in article relevant to 1999?................................................................................. [image]Yes ....... No

IF THE RESPONSE TO QUESTION 6, 7, OR 8 IS NO-STOP, REJECT ARTICLE

## I. Study Design

6 Type of study: CIRCLE ALL THAT APPLY
  a. Safety of regional anesthesia
  b. Comfort/pain control of regional anesthesia
  c. Sedation strategies (IV/Oral)
  d. Personnel, setting, and outcomes
  e. Effectiveness of anesthesia
  f. Other: _______________________

10 Indicate study design. (Circle the one letter listed below that describes the study design.)
  a. Randomized trial
  b. Non-randomized controlled trial
  c. Cohort
  d. Case-control
  e. Cross-sectional
  f. Clinical series
  g. Other (specify type)_____________

*11a. If cohort or case-control, what was type of control? (circle response)
a | b | c
Concurrent | Historical | Can't tell
*11b Were controls matched? (circle response)
a | b | c
Yes | No | Cant'tell
*11c Was the choice of control group reasonable? (circle response)
a | b | c
Yes | No | Cant'tell

## II. REPRESENTATIVENESS OF STUDY POPULATION(Indicate your response by circling the letter)

12 Was the setting and population from which study sample drawn described and dates of study reported?
  a. adequate (setting AND population described AND start date and end date specified)
  b. fair (one or more of these NOT reported OR poor descriptions)
  c. inadequate (not specified)
  d. not applicable
13 Were detailed inclusion/exclusion criteria provided, so as to allow replication?
  a. adequate (detailed description of specific inclusion and exclusion criteria OR statement that all consecutive patients enrolled)
  b. fair (some description but would be difficult to replicate based on information provided OR consecutive patients without describing exclusion)
  c. inadequate (minimal description or none at all)
  d. not applicable
14 Was there information on patients excluded/not participating provided?
  a. adequate (all reasons for exclusion AND # excluded or no exclusions)
  b. fair (only one of above criteria specified or information not quite sufficient to allow replication)
  c. inadequate (none of above criteria specified)
  d. not applicable
15 Does the study describe patients' characteristics at enrollment in 2 key areas? demographics: age co-morbidities: h/o Hypertension h/o DM h/o CAD ASA risk class Other
  a. good (must include age and ASA or 2+ major comorbidities)
  b. adequate (at least age and 1 comorbidity)
  c. fair (at least age)
  d. inadequate
  e. not applicable
16 Describe exclusion criteria, if provided in report:_____________________________________________________ _______________________________________________________________________________________________________ _______________________________________________________________________________________________________ _______________________________________________________________________________________________________

## III. BIAS AND CONFOUNDING(Indicate your response by circling the letter)

17 Was assignment of patients to study groups randomized?
  a. yes (investigators could not predict assignment)
  b. partial (used DOB, date of admission, hospital #, or alternating scheme for assignment OR did not state method of randomization)
  c. not randomized
  d. unclear
  e. not applicable
18 Was there masking of treatment supervisors, patients, and outcome assessors?
  a. adequate (all appropriate individuals masked, including all treatment arms)
  b. fair (only 2 of the 3 masked, or some but not all of the arms masked in all 3 ways)
  c. poor (only 1 of the 3 masked)
  d. none of the 3 masked or unknown
  e. not applicable
19 Did the groups have any important differences on key factors at baseline? key factors: demographic indicators medical comorbidity indicators
  a. groups equivalent in both demographic characteristics AND medical comorbidity
  b. groups have an important difference on demographic characteristics OR medical comorbidity
  c. groups differ in both demographic characteristics AND medical comorbidity
  d. analysis not done
  e. not applicable or impossible to tell

## IV. DESCRIPTION OF THERAPY(Indicate your response by circling the letter)

20 Was there a complete description of the main anesthesia regimen of interest in the study?
  a. adequate (protocol could be replicated given the completeness and detail e.g. procedures, drugs, dose, route, duration)
  b. fair (some detail but insufficient to ensure replication)
  c. inadequate (very little or no detail)
  d. not applicable
21 Was there a description of other ancillary medications/procedures given to each treatment group?
  a. adequate (e.g. drug name, dose, frequency, route, duration, procedure)
  b. fair (some description but would be difficult to replicate with information provided)
  c. inadequate (not described or not mentioned)
  d. not applicable
22 Were there any differences in ancillary medications/procedures between the treatment groups which could have affected results?
  a. no differences (essentially the same)
  b. minor differences (minor differences in protocols)
  c. major differences or differences not discussed (e.g. different drugs/procedures between groups)
  d. can't tell
  e. not applicable
23 Was there an adequate report of the duration of surgery?
  a. adequate (shows distribution)
  b. fair (mean or median only)
  c. inadequate
  d. not applicable
24 Were there any differences in duration of surgery between the treatment groups which could have affected results?
  a. no differences minor differences
  b. major differences or differences not discussed
  c. can't tell
  d. not applicable

## V. OUTCOMES AND FOLLOW-UP(Indicate your response by circling the letter)

25 Which of the following outcomes were reported?
  1. efficacy of block
  2. complications of block
  3. efficacy of sedation
  4. complications of sedation
  a. 2 or more of the above
  b. 1 of the above
  c. none of the above
26 Were the frequency and duration of evaluations standardized?
  a. yes
  b. no
  c. can't tell
  d. not applicable
27 Were the outcome assessment procedures objective?
  a. adequate (accepted or reasonable measurement method)
  b. fair
  c. inadequate (inadequate or absent)
  d. not applicable
28 What was the planned length of follow-up?
  a. 7+ days
  b. 1 day
  c. discharge
  d. duration of surgery
  e. immediate effect of anesthesia
  f. not stated
  g. not applicable (e.g., study on acute conversion only)

## VI. STATISTICAL QUALITY AND INTERPRETATION(Indicate your response by circling the letter)

29 For primary endpoints, is the magnitude of difference between groups AND an index of variability (e.g. test statistic, p value, standard error, confidence interval) stated?
  a. adequate (both reported with index of variability using standard error or confidence intervals)
  b. fair (both reported with index of variability using only test statistic or p value)
  c. inadequate (one or both not reported)
  d. not applicable
30 Were the appropriate analyses and statistical tests performed?
  a. adequate (yes for all analyses)
  b. fair (yes for only some of the analyses)
  c. inadequate (not for any of the analyses or can't tell)
  d. not applicable
31 If groups were not comparable at study onset, was there adjustment for potential confounders with multivariate or stratified analyses AND were confounders coded in a way to make such control adequate?
  a. adequate (adjustment done AND confounders appropriately coded)
  b. fair (adjustment done BUT confounders not coded appropriately OR coding unclear)
  c. inadequate (adjustment not done OR comparability not previously reported)
  d. not applicable
32 Were cross-overs handled appropriately in analysis?
  a. sensitivity analysis
  b. by intention to treat
  c. by 'treatment received' analysis only
  d. by none of the above
  e. unknown
  f. not applicable