# Appendix F. Abstract Review Form

Cataract Abstract Review Form | Reviewer: _________ Data Entry: _________

Delete, because article(check one):; - only addressed general anesthesia; - did not address human data; - Adults are not part of the study population; - not in English; - has fewer than 100 cases (for Case Series only); - No original data; - Others:_______________________________; Do not go on if any of above item is checked | - This article does not apply to any above study questions.; - However, get article for reference regarding____________________; - Unclear: get article to decide; Any comments to be tagged _________________________________________________________ _________________________________________________________
  Study Topics; - Regional Anesthesia; - Sedation; - Patient characteristics