# Appendix E. List of Hand-Searched Journals

Priority Journals

Coverage in Databases as of January 25, 1999

Journal name | Cochrane hand searching (dates of registered searches) ^1^ | PubMed (date of most recent citation)
American Journal of Ophthalmology | None | Dec 1998
Anesthesiology | 1980, 1986-90, 1993 | Jan 1999
Anesthesia and Analgesia | 1988-present | Jan 1999
Archives of Ophthalmology | 1964-93 | Dec 1998
British Journal of Ophthalmology | 1948-93 | Sept 1998
Canadian Journal of Anaesthesia | 1954-93 | Oct 1998
Journal of Cataract Refractive Surgery | 1993-95 | Jan 1999
Journal of Clinical Anesthesia | 1988-present | Dec 1998
Ophthalmic Surgery | 1968-97 | July/Aug 1995
Ophthalmology | 1970, 1981-93 | Dec 1998

1 In addition to hand searching, the Cochrane Collaboration also searches electronic databases, such as MEDLINE and EMBASE, for controlled trials.