# Appendix D. Search Strategies

Preliminary PubMed Search

(("cataract"[MeSH Terms] OR cataract*[Text Word]) AND (((("anesthesia"[MeSH Terms] OR anesthe*[Text Word]) OR anaesthe*[Text Word]) OR "hypnotics and sedatives"[MeSH Terms]) OR sedat*[Text Word]))

Within database of results from above search

remove: letter [pt] editorial [pt] review [pt] non-English language animal studies

limit to specific study designs: randomized controlled trial [pt] clinical trial [pt] (not included in above) follow-up studies [MeSH Terms] OR follow-up* [Text Word] cohort studies [MeSH Terms] OR cohort [Text Word] comparative study [MeSH Terms] OR compara* [Text Word] experimental study [Text Word] or experiment* [Text Word] treatment outcome [MeSH Terms] trial* [Text Word] random* [Text Word] case series [Text Word] case control [Text Word]

CENTRAL Core Search Strategy

1. cataract*.me
2. cataract*
3. #1 or #2
4. anesthesia*.me
5. anesthe*
6. anaesthe*
7. #4 or #5 or #6
8. hypnotics-and-sedatives*.me
9. sedat*
10. #8 or #9
11. #7 or #10
12. #3and #11

PubMed Core Search Strategy

Core cataract search strategy

(cataract [mh] OR cataract*[tw]) AND (anesthesia [mh] OR anesthe*[tw] OR anaesthe*[tw] OR hypnotics and sedatives [mh] OR sedat*[tw]) combined with:

Optimal search strategy for the retrieval of controlled trials using PubMed : Phases 1, 2 and 3 (Robinson, Hinegardner, and Lansung, 1998)

(randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized controlled trials [mh] OR random allocation [mh] OR double-blind method [mh] OR single-blind method [mh] OR clinical trial [pt] OR clinical trials [mh] OR (clinic* [tw] AND trial* [tw]) OR ((singl* [tw] OR doubl* [tw] OR trebl* [tw] OR tripl* [tw]) AND (mask* [tw] OR blind* [tw])) OR (latin [tw] AND square [tw]) OR placebos [mh] OR placebo* [tw] OR random* [tw] OR research design [mh:noexp] OR comparative study [mh] OR evaluation studies [mh] OR follow-up studies [mh] OR prospective studies [mh] OR cross-over studies [mh] OR control* [tw] OR prospectiv* [tw] OR volunteer* [tw] OR case report[mh] OR (case[tw] AND series[tw])) NOT (animal [mh] NOT human [mh])

NOTE: items underlined added to strategy for the cataract literature search

Modified PubMed Core Search Strategy

Modified core cataract search strategy

((("eye"{MeSH Terms] AND ("surgery"[MeSH Terms] OR surg*[tw])) AND (((anesthesia [MeSH Terms] OR anesthe*[tw] OR anaesthe*[tw]) OR hypnotics and sedatives [MeSH Terms] OR sedat*[tw])) NOT (("cataract"[MeSH Terms] OR cataract*[tw])) combined with:

Optimal search strategy for the retrieval of controlled trials using PubMed: Phases 1, 2 and 3 (Robinson, Hinegardner, and Lansung, 1998)

(randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized controlled trials [mh] OR random allocation [mh] OR double-blind method [mh] OR single-blind method [mh] OR clinical trial [pt] OR clinical trials [mh] OR (clinic* [tw] AND trial* [tw]) OR ((singl* [tw] OR doubl* [tw] OR trebl* [tw] OR tripl* [tw]) AND (mask* [tw] OR blind* [tw])) OR (latin [tw] AND square [tw]) OR placebos [mh] OR placebo* [tw] OR random* [tw] OR research design [mh:noexp] OR comparative study [mh] OR evaluation studies [mh] OR follow-up studies [mh] OR prospective studies [mh] OR cross-over studies [mh] OR control* [tw] OR prospectiv* [tw] OR volunteer* [tw] OR case report[mh] OR (case[tw] AND series[tw])) NOT (animal [mh] NOT human [mh])

NOTE: items underlined added to strategy for the cataract literature search