# Appendix B. Question Refinement Mailing

Potential Topics for Evidence-Based Report on Anesthesia Management for Cataract Surgery Name:

The Johns Hopkins University Evidence-Based Practice Center will be developing an evidence report on management of anesthesia for cataract surgery for the Agency for Health Care Policy and Research in the U.S. Department of Health and Human Services. We are soliciting input from experts with varied perspectives on key questions regarding anesthesia during cataract surgery.

PLEASE ASSIST US IN IDENTIFYING, FROM YOUR PERSPECTIVE AS_________________, WHAT ARE THE MOST IMPORTANT QUESTIONS THAT SHOULD BE ADDRESSED.

Please return your form by December 14.

Please read the following seventeen questions regarding anesthesia management during cataract surgery that are being considered for in-depth examination in our study. Write in the space provided any other questions that you think are particularly relevant or controversial. Then, please prioritize the six questions that you deem to be the most important for us to address in the planned evidence report, and rank them in order of importance, with number 1 being the most important, (you may include in this ranking any additional questions you have written).

Rank 1-6 1=most important | Possible Questions | Comments
| Is there evidence supporting the use of preoperative medication and intraoperative sedation?
| Is there evidence favoring specific pre-and intraoperative sedation strategies/drugs?
| What are the complication rates of the medications used for pre- and intraoperative sedation?
| What are the costs and benefits associated with different approaches to sedating the patient for intraocular surgery?
| Which regional anesthetic agent (or combination of agents) results in the least sensation of discomfort for the patient?
| Is there evidence supporting the routine use of one form of regional anesthesia over another Re: adequacy of pain control/comfort/patient satisfaction?
| Is there evidence supporting the use of one form of regional anesthesia over another Re: complication rates?
| Is there evidence to support the use of supplemental agents to enhance local anesthesia performance (e.g., hyaluronidase, heat and ph.. adjustment) for retro/peribulbar injections?
| Is there evidence that the rate of complications associated with retro- and peribulbar injections varies with the training (experience, subspecialty, etc.) of the person administering the block?
| Is there evidence supporting the safety and effectiveness of intracameral lidocaine for ocular anesthesia
| What is the cost-effectiveness of different strategies for managing pain during cataract surgery?
| What is the cost-effectiveness of different strategies for managing blood pressure and heart rate during cataract surgery?
| What is the cost-effectiveness of different strategies for managing anxiety during cataract surgery?
| Is there evidence that the level of training of the individual providing anesthesia monitoring (e.g., anesthesiologist, nurse anesthetist, nurse) is associated with varying patient outcomes?
| Is there evidence for an effect of patient characteristics (e.g., medical comorbidity and current medications) on outcomes of anesthesia management for cataract surgery?
| Is there evidence that the location (hospital, ASC, office) of anesthesia management for cataract surgery is related to patient outcome?
| Is there evidence of the level or intensity of monitoring (e.g., PO_2_, blood pressure, EKG) necessary to optimize patient care?
| Is there evidence that specific patient characteristics favor the use of one form of regional anesthesia (block, topical, etc.) over another?
| Is there evidence that the content of a preoperative medical examination or the training (e.g., surgeon, anesthesiologist, nurse practitioner, other) of the individual performing it effects outcomes of anesthesia management for cataract surgery?
| (OTHER)

How might your organization use an evidence report on anesthesia management for cataract surgery? Check all that apply

- Would use report to facilitate development of a new practice guideline on management of anesthesia during cataract surgery
- Would use report to assess the appropriateness or our organization's existing guidelines on management of anesthesia during cataract surgery
- Would use report to prepare educational materials for physicians
- Would use report to prepare educational materials for patients
- Other (please specify)__________________________________________________
- Other (please specify)___________________________________________________

Other Comments?___________________________________________________________ _____________________________________________________________________________ _____________________________________________________________________________ _____________________________________________________________________________ _____________________________________________________________________ ******************************************************************************

Completed by:_____________________________________________________________
| Last Name | First Name

Telephone #:___(______)______________ | Fax #:___(_______)___________________

Thank you for your input!