# Appendix S. Medicare Claims Analysis Tables

Refer to Table

Procedure | Inpatient hospital | Outpatient hospital | Ambulatory surgery center | Office-based surgery
Procedure | Inpatient hospital | Outpatient hospital | Ambulatory surgery center | Office-based surgery
Number of procedures | 1,754 | 81,643 | 52,414 | 2,773
Readmission within 1 day of surgery (per 1,000 cases) | 15.39 | 1.34 | 1.05 | 2.88
Readmission within 7 days of surgery (per 1,000 cases) | 19.95 | 3.56 | 2.82 | 4.69

Risk factor | P value | Odds ratio
Risk factor | P value | Odds ratio
Age 80-84 | <0.01 | 1.209
Age > 85 | <0.01 | 1.645
Female | 0.02 | 0.889
Prior admission to a hospital | <0.01 | 1.754
Charleson Index | <0.01 | 1.083
Inpatient hospital | <0.01 | 2.54
Ambulatory surgery center | <0.01 | 0.849
Office-based setting | 0.144 | 1.26