# Appendix Q. Decision Analysis Tables

Refer to Table

Variable | Baseline value | Plausible range
Cost of admission | $595 | $500-700
Anesthesiologist cost | $100 | $75-150
Anesthesiologist cost, on call | $25 | $9.30-37.50
Cost of conversion from topical to block anesthesia | $5 | $1-9
Cost of general anesthesia | $50 | $25-150
Cost of anesthesia supplies | $65 | $20-100
Cost of preoperative tests | $120 | $70-180
Cost of treating intraoperative cardiovascular instability | $5 | $1-9
Cost of treating postoperative nausea and vomiting | $15 | $10-20
Cost of oral sedation | $5 | $1-9
Cost of intravenous sedation | $30 | $15-50
Cost of topical anesthesia (including intracameral block) | $5 | $1-9
Cost of peribulbar or retrobulbar block anesthesia | $5 | $1-9

1 In the decision model, the overall preference value for situations where one or more complications occurred was determined by multiplying the baseline preference of the anesthesia management strategy by the disutility factor(s) of the complication(s) that occurred. Disutility factors represent the preference value assigned to a scenario with a complication divided by the preference value assigned to a scenario without the complication.

2 The lowest value of the plausible range for a given disutility factor was based on the lowest disutility factor assigned by an expert to the complication, and the highest value of the plausible range was based on the highest value assigned by an expert.

Refer to Table

Baseline scenarios for anesthesia management | Preference value | Plausible range
Baseline scenarios for anesthesia management | Preference value | Plausible range
Block anesthesia with intravenous sedation administered by an anesthesiologist | 0.89 | 0.80-0.98
Topical anesthesia with intravenous sedation administered by an anesthesiologist | 0.66 | 0.30-0.95
Block anesthesia with oral sedation preoperatively, with an anesthesiologist on call for additional sedation | 0.75 | 0.50-0.95
Block anesthesia with oral sedation preoperatively, with no anesthesiologist on call for additional sedation | 0.62 | 0.20-0.85
Topical anesthesia with oral sedation preoperatively, with an anesthesiologist on call for additional sedation | 0.56 | 0.10-0.90
Topical anesthesia with oral sedation preoperatively, with no anesthesiologist on call for additional sedation | 0.50 | 0.50-0.90

Complication | Disutility factor^1^ | Plausible range^2^
Complication | Disutility factor^1^ | Plausible range^2^
Being admitted postoperatively | 0.63 | 0.31-0.80
Being converted from topical to block anesthesia | 0.90 | 0.42-0.94
Experiencing cardiovascular instability intraoperatively | 0.81 | 0.71-0.90
Being converted to general anesthesia from block anesthesia | 0.47 | 0.30-0.55
Being converted from topical anesthesia to general anesthesia | 0.86 | 0.44-1.0
Experiencing nausea and vomiting postoperatively | 0.72 | 0.42-0.75

1 In the decision model, the overall preference value for situations where one or more complications occurred was determined by multiplying the baseline preference of the anesthesia management strategy by the disutility factor(s) of the complication(s) that occurred. Disutility factors represent the preference value assigned to a scenario with a complication divided by the preference value assigned to a scenario without the complication.

2 The lowest value of the plausible range for a given disutility factor was based on the lowest disutility factor assigned by an expert to the complication, and the highest value of the plausible range was based on the highest value assigned by an expert.

Refer to Table

Variable | Baseline value | Plausible range
Probability of admission postsurgery with intravenous sedation | 0.006 | 0.0047-0.0072
Probability of admission postsurgery with oral sedation | 0.0098 | 0.003-0.017
Probability of being converted from topical to block anesthesia | 0.06 | 0.02-0.1
Probability of being converted to general anesthesia from initial intravenous sedation | 0.0036 | 0.0001-0.1
Probability of being converted to general anesthesia from initial oral sedation and topical anesthesia | 0.0065 | 0.0001-0.03
Probability of experiencing cardiovascular instability intraoperatively while receiving intravenous sedation | 0.0277 | 0.0251-0.0304
Probability of experiencing cardiovascular instability intraoperatively while receiving oral sedation | 0.0125 | 0.0067-0.0206
Probability of nausea and vomiting postoperatively after having received intravenous sedation intraoperatively | 0.044 | 0.0408-0.0475
Probability of nausea and vomiting postoperatively after having received oral sedation intraoperatively | 0.0347 | 0.0213-0.0481

Refer to Table

Rank (lowest to highest cost) | Strategy | Expected cost
1 | Strategy 3 (block anesthesia with oral sedation preoperatively, with no anesthesiologist on call for additional sedation) | $17.16
2 | Strategy 6 (topical anesthesia with oral sedation preoperatively, with no anesthesiologist on call for additional sedation) | $17.46
3 | Strategy 2 (block anesthesia with oral sedation preoperatively, with an anesthesiologist on call for additional sedation) | $42.16
4 | Strategy 5 (topical anesthesia with oral sedation preoperatively, with an anesthesiologist on call for additional sedation) | $42.46
5 | Strategy 1 (block anesthesia with intravenous sedation administered by an anesthesiologist) | $324.55
6 | Strategy 4 (topical anesthesia with intravenous sedation administered by an anesthesiologist) | $324.85

Refer to Table

Rank (greatest to least utility) | Strategy | Expected net preference value
1 | Strategy 1 (block anesthesia with intravenous sedation administered by an anesthesiologist) | 0.874
2 | Strategy 2 (block anesthesia with oral sedation preoperatively, with an anesthesiologist on call for additional sedation) | 0.736
3 | Strategy 4 (topical anesthesia with intravenous sedation administered by an anesthesiologist) | 0.644
4 | Strategy 3 (block anesthesia with oral sedation preoperatively, with no anesthesiologist on call for additional sedation) | 0.603
5 | Strategy 5 (topical anesthesia with oral sedation preoperatively, with an anesthesiologist on call for additional sedation) | 0.550
6 | Strategy 6 (topical anesthesia with oral sedation preoperatively, with no anesthesiologist on call for additional sedation) | 0.484