# Appendix O. Summary of Quality Review

Refer to Table

Scale | Mean (percent of possible points) | Range (percent of possible points)
Representativeness | 38 | 0-100
Bias^1^ | 48 | 0-100
Description of therapy | 37 | 0-86
Outcomes | 55 | 0-80
Statistical quality^1^ | 40 | 0-75
Overall | 43 | 3-76

1 Includes only 118 controlled studies.