# Appendix N. Reasons for Article Exclusion

Refer to Table

Reason for Exclusion | Percent of Excluded Articles (N=51)
Did not address human data | 0.0
Did not address anesthesia management for cataract surgery | 3.8
Did not report data separately for cataract surgery | 28.9
Only addressed general anesthesia | 0.0
Adults were not part of the population studied | 0.0
No original data | 9.6
Was not controlled trial or case series > 100 patients | 19.2
Data not extractable as reported | 3.8
Meeting abstract | 5.7
Outcomes reported not directly relevant to study priorities | 17.3
Regional anesthesia technique reported not relevant to 1999 | 1.9
Sedation technique reported not relevant to 1999 | 9.6