# Appendix M. Articles Excluded During Full Article Abstraction

Aboul-Eish E. Is general anaesthesia better than local analgesia for cataract extraction? Bull Ophthalmol Soc Egypt 1968;61(65):263-5.

Abrahamson IA, Scioville G. Intravenous diazepam as an adjunct to local anesthesia in ophthalmic surgery. Ann Ophthalmol 1975 Apr;7(4):567-70.

Ali-Melkkila TM, Virkkila M, Jyrkkio H. Regional anesthesia for cataract surgery: Comparison of retrobulbar and peribulbar techniques. Reg Anesth 1992 Jul;17(4):219-22.

Arnold PN. Prospective study of a single-injection peribulbar technique. J Cataract Refract Surg 1992 Mar;18(2):157-61.

Barker JP, Vafidis GC, Robinson PN, et al. Plasma catecholamine response to cataract surgery: A comparison between general and local anaesthesia. Anaesthesia 1991 Aug;46(8):642-5.

Barker JP, Vafidis GC, Hall GM. Postoperative morbidity following cataract surgery. A comparison of local and general anaesthesia. Anaesthesia 1996 May;51(5):435-7.

Behndig A, Linden C. Aqueous humor lidocaine concentrations in topical and intracameral anesthesia. J Cataract Refract Surg 1998 Dec;24(12):1598-601.

Beri S, Biswas NR, Shende DR, et al. Injectable centbucridine and lidocaine hydrochloride for intraocular surgery. Ophthalmic Surg Lasers 1997 Dec;28(12):1027-9.

Bloomberg LB, Pellican KJ. Topical anesthesia using the Bloomberg SuperNumb Anesthetic Ring. J Cataract Refract Surg 1995 Jan;21(1):16-20.

Brady MD, Hustead RR, Robinson RH, et al. Dilution of proparacaine in balanced salt solution reduces pain of anesthetic instillation in the eye. Reg Anesth 1994 May;19(3):196-8.

Brahma AK, Pemberton CJ, Ayeko M, et al. Single medial injection peribulbar anaesthesia using prilocaine. Anaesthesia 1994 Nov;49(11):1003-5.

Brydon CW, Basler M, Kerr WJ. An evaluation of two concentrations of hyaluronidase for supplementation of peribulbar anaesthesia. Anaesthesia 1995 Nov;50(11):998-1000.

Campbell DN, Lim M, Muir MK, et al. A prospective randomised study of local versus general anaesthesia for cataract surgery. Anaesthesia 1993 May;48(5):422-8.

Campbell IT, Sparrow CH, Duthie AM. Ophthalmic anaesthesia under gamma-hydroxybutyrate and local analgesia. A method for developing countries. Anaesthesia 1972 Jul;27(3): 319-26.

Chapu BA, Ahmed M, Dhar CL. Mandrax as a premedication in cataract surgery. Indian J Ophthalmol 1977 Apr;25(1):33-4.

Chopdar A. Sedation for cataract surgery. Comparison of Carbrital and neuroleptanalgesia. Br J Ophthalmol 1970 Oct;54(10):687-9.

Coelho ET, Gomes EB, Martins HS, et al. Prilocaine: An old anesthetic agent and a new ophthalmic procedure. Ophthalmic Surg 1993 Sep;24(9):612-6.

Crawford M, Kerr WJ. The effect of hyaluronidase on peribulbar block. Anaesthesia 1994 Oct;49(10):907-8.

Cummings AB, Konig HL. Effect of oxygen and air inhalation during cataract surgery on blood gas parameters. J Cataract Refract Surg 1996 Nov;22(9):1236-9.

Dempsey GA, Barrett PJ, Kirby IJ. Hyaluronidase and peribulbar block. Br J Anaesth 1997 Jun;78(6):671-4.

Erb T, Sluga M, Hampl KF, et al. Preoperative anxiolysis with minimal sedation in elderly patients: Bromazepam or clorazepate-dipotassium? Acta Anaesthesiol Scand 1998 Jan;42(1):97-101.

Fichman RA. Use of topical anesthesia alone in cataract surgery. J Cataract Refract Surg 1996 Jun;22(5):612-4.

Forrest JB, Lam L, Woo J, et al. Oxygen desaturation in elderly patients during cataract surgery. Can J Anaesth 1990 May;37(4 Pt 2):S50.

Forrest JB, Lam L, Woo J, et al. Recovery after neuroleptanalgesia for cataract surgery. Can J Anaesth 1990 May;37(4 Pt 2):S82.

Francis IC, Schumacher RS, Haylen MJ. Assisted local anaesthesia for cataract surgery (ALACS). Aust N Z J Ophthalmol 1987 Aug;15(3):185-91.

Ghanchi FD, Khan MY. Sublingual lorazepam as premedication in peribulbar anesthesia. J Cataract Refract Surg 1997 Dec;23(10):1581-4.

Gills JP, Rudisill JE. Bupivacaine in cataract surgery. Ophthalmic Surg 1974 Dec;5(4):67-70.

Hamilton RC. Retrobulbar block revisited and revised. J Cataract Refract Surg 1996 Nov;22(9):1147-50.

Hulquist CR. Painless wakeful peribulbar block achieved safely with a single transconjunctival injection. Ophthalmic Surg 1995 May;26(3):200-4.

Karhunen U, Jonn G. A comparison of memory function following local and general anaesthesia for extraction of senile cataract. Acta Anaesthesiol Scand 1982 Aug;26(4):291-6.

Kennerdell JS, Rydze D, Robertson M. Comparison of retrobulbar Marcaine and combined Marcaine-carbocaine in ophthalmic surgery. Ann Ophthalmol 1976 Oct;8(10):1236-40.

Laaka V, Nikki P, Tarkkanen A. Comparison of bupivacaine with and without adrenalin and mepivacaine with adrenalin in intraocular surgery. Acta Ophthalmol (Copenh) 1972;50(2):229-39.

Meyer D, Hamilton RC, Loken RG, et al. Effect of combined peribulbar and retrobulbar injection of large volumes of anesthetic agents on the intraocular pressure. Can J Ophthalmol 1992 Aug;27(5):230-2.

Neatrour GP, Lederman IR. Reducing fire hazard during ophthalmic surgery by using compressed air. Ophthalmic Surg 1989 Jun;20(6):430-2.

Nicoll JM, Treuren B, Acharya PA, et al. Retrobulbar anesthesia: The role of hyaluronidase. Anesth Analg 1986 Dec;65(12):1324-8.

Palve H, Ali-Melkkila T. Oxygenation during local anaesthesia for cataract surgery. Acta Anaesthesiol Scand 1991 Feb;35(2):181-4.

Polkinghorne PJ. Inadvertent perforation of the globe during regional anaesthesia. Aust N Z J Ophthalmol 1996 Feb;24(1):43-5.

Rauz S, Subramaniam S. Sub-Tenon's anesthesia and orbicularis oculi function. Ophthalmic Surg Lasers 1997 Sep;28(9):727-30.

Rinkoff JS, Doft BH, Lobes LA. Management of ocular penetration from injection of local anesthesia preceding cataract surgery. Arch Ophthalmol 1991 Oct;109(10):1421-5.

Risdall JE, Geraghty IF. Oxygenation of patients undergoing ophthalmic surgery under local anaesthesia. Anaesthesia 1997 May;52(5):492-5.

Roman SJ, Chong Sit DA, Boureau CM, et al. Sub-Tenon's anaesthesia: an efficient and safe technique. Br J Ophthalmol 1997 Aug;81(8):673-6.

Sanford DK, Minoso Y, Belyea DA. Response of intraocular pressure to retrobulbar and peribulbar anesthesia. Ophthalmic Surg Lasers 1998 Oct;29(10):815-7.

Suzuki R, Kawata K, Kuroki S, et al. A comparison of blood pressure changes in phacoemulsification surgery with topical and retrobulbar block local anesthesia: Part II. Ophthalmologica 1997;211(6):327-31.

Suzuki R, Kuroki S, Fujiwara N, et al. The effects of phacoemulsification cataract surgery via local anesthesia on preoperative and postoperative blood pressure levels. Ophthalmology 1997 Feb;104(2):216-22.

Teichmann KD, Uthoff D. Retrobulbar (intraconal) anesthesia with a curved needle: Technique and results. J Cataract Refract Surg 1994 Jan;20(1):54-60.

van Rij G, Renardel de Lavalette JG, Baarsma GS, et al. Effect of oxybuprocaine 0.4% in preventing surgically induced miosis. Br J Ophthalmol 1984 Apr;68(4):248-51.

Virkkila M, Ali-Melkkila T, Soini H, et al. Pharmacokinetics and effects of i.m. alfentanil as premedication for day-case ophthalmic surgery in elderly patients. Br J Anaesth 1993 Oct;71(4):507-11.

Walker AK. Neuroleptanalgesia for intra-ocular surgery: experience in a developing country. Anaesthesia 1976 Jun;31(5):690-4.

Walters G, McKibbin M. The value of pre-operative investigations in local anaesthetic ophthalmic surgery. Eye 1997;11(Pt 6):847-9.

Wang HS. Peribulbar anesthesia for ophthalmic procedures. J Cataract Refract Surg 1988 Jul;14(4):441-3.

Wood G, Simpson T. The effect of hyaluronidase on the speed of onset of retrobulbar anaesthesia. Can J Anaesth 1990 May;37(4 Pt 2):S62.