# Appendix L. Abstract Review Summary

## Citations Removed

Citations deleted during abstract review process:

Reason for Removal | Number of Citations
Both reviewers agreed to delete | 193
Both reviewers agreed citation not applicable | 237
One reviewer deleted, one said not applicable | 105
Duplicates | 9
TOTAL deleted during abstract review: | 544

See footnotes on next page.

1 Reviewers did not have to agree; total number of reasons will be more than the 544 citations deleted.

2 Includes three citations not received by end of article abstraction.

3 Reviewers may select multiple topics and need not agree on classification; number of citations by topic is, therefore, greater than total number of citations being reviewed in article review process.

Reasons for deletion:

Reason for Deletion | Number of Citations^1^
Fewer than 100 cases (for case series only) | 181
Only address general anesthesia | 52
No original data | 27
Adults not part of study population | 25
Did not address human data | 4
Removed, not applicable | 237
Other | 39

See footnotes on next page.

1 Reviewers did not have to agree; total number of reasons will be more than the 544 citations deleted.

Citations Kept (included in article review process)

Total number kept: | 195^2^
Classification by topic:

Topic | Number of Citations^3^
Regional anesthesia | 157
Sedation | 45
Patient characteristics | 2
Regional anesthesia and sedation | 1

See footnotes on next page.

2 Includes three citations not received by end of article abstraction.

3 Reviewers may select multiple topics and need not agree on classification; number of citations by topic is, therefore, greater than total number of citations being reviewed in article review process.