# Appendix K. Summary of Searches

Refer to Table

Source | Search strategy | Date | Number of citations
Source | Search strategy | Date | Retrieved | Unique (included in abstract review process) | Included in article review process
PubMed | Preliminary | Dec 23, 1998 | 283 | 283 | 163
CENTRAL Issue 1 1999 | CENTRAL core | Feb 1, 1999 | 192 | 16 | 4
PubMed | PubMed core | Feb 9, 1999 | 529 | 182 | 9
PubMed | PubMed core | Apr 5, 1999 | 537 | 14 | 1
Hand search | Table of contents of priority journals and reference lists of key reviews | Apr 8, 1999 | 22 | 13 | 3
PubMed | Expanded | May 3, 1999 | 294 | 231 | ^1^ 15
Total | -- | -- | 1,857 | 739 | 195

1 Includes one citation for which abstract review could not be completed (full article review required; citation not received).

Note: Cataract trials database currently contains 195 records.