# Appendix J. Peer Review Response Form for Draft Report

## Evidence Report on Anesthesia Management During Cataract Surgery Review of Draft Evidence Report

### Methods

1. Are the inclusion/exclusion criteria for both the search strategy and the literature abstraction clinically reasonable and clearly stated? [image] Yes [image] No, if no, please comment.
2. Are the questions addressed by the review clearly articulated? [image]Yes [image] No, if no, please comment.
3. Is it clear what patient populations are being discussed? [image] Yes [image] No, if no, please comment.
4. Is it clear what interventions are being discussed? [image] Yes [image] No, if no, please comment.
5. Is it clear what outcomes are being discussed? [image] Yes [image] No, if no, please comment.

### Quality Assessment Methodology

6 Have we captured the important aspect of quality of studies in our assessment? [image] Yes [image] No, if no, please comment.

### Clinical Abstraction Methodology

7 Were important areas overlooked? [image] Yes [image] No, if yes, please comment.

### Evidence

1. Given the ways the data were presented in the articles, was the evidence synthesized in a reasonably understandable way? [image] Yes [image] No, if no, please comment.
2. Was the literature content clearly summarized? [image] Yes [image] No, if no, please comment.

### Interpretation of Results

1. Is the report clear enough about the strength of the evidence available for clinical decisionmaking on the most common strategies used for anesthesia management during cataract surgery? [image] Yes [image] No, if no, please comment.
2. Do the conclusions flow from the evidence (strength or weakness) that is reviewed? [image] Yes [image] No, if no, please comment.
3. Are there any assumptions or gaps that need to be more clearly described? [image] Yes [image] No, if yes, please comment.

### Usefulness of Report

1. Are the results of this report presented in a manner that will be useful for organizations making guidelines or policy? [image] Yes [image] No, if no, please comment.
2. Can you think of additional research implications beyond those raised? [image] Yes [image] No, if yes, please comment.

Signature:_________________________________________ Date:_______________________