# Appendix A. Peer Reviewers

Participants in the Peer Review Process Evidence Report on Anesthesia Management During Cataract Surgery
Reviewer | Organization
Dr. James Arens | American Society of Anesthesiologists
Mr. Jeffery Beutler | American Association of Nurse Anesthetists
Dr. Gary Fanning | Society for Excellence in Eye Care Ophthalmic Anesthesia Society
Dr. William Golden | American College of Physicians-American Society of Internal Medicine
Ms. Jacqueline Harden | Technical Expert Consultant
Dr. Michael LeFevre | American Association of Family Physicians
Dr. Stephen Obstbaum | Technical Expert Consultant American Academy of Ophthalmology
Dr. Brent Petty | Technical Expert Consultant
Dr. Marymargaret Sharp-Pucci | Blue Cross/Blue Shield Association
Dr. Robert Stoelting | Anesthesia Patient Safety Foundation
Dr. John Whyte | Health Care Financing Administration
Dr. Henry Wong | Technical Expert Consultant