# Appendixes

Appendix A. Peer Reviewers

Appendix B. Question Refinement Mailing

Appendix C. Causal Pathway of Anesthesia Management for Cataract Surgery

Appendix D. Search Strategies

Appendix E. List of Hand-Searched Journals

Appendix F. Abstract Review Form

Appendix G. Article Quality Assessment Form

Appendix H. Article Content Abstraction Form

Appendix I. Questions for Literature Synthesis

Appendix J. Peer Review Response Form for Draft Report

Appendix K. Summary of Searches

Appendix L. Abstract Review Summary

Appendix M. Articles Excluded During Full Article Abstraction

Appendix N. Reasons for Article Exclusion

Appendix O. Summary of Quality Review

Appendix P. Decision Tree

Appendix Q. Decision Analysis Tables

Appendix R. Average Expected Cost Versus Average Expected Preference Value for Six Anesthesia Strategies

Appendix S. Medicare Claims Analysis Tables