# Acronyms/Abbreviations

1DR | First Degree Relatives
2DR | Second Degree Relatives
3DR | Third Degree Relative
BED | Best Estimate Diagnosis
BRCAPRO | Breast Cancer Program
BOADICEA | Breast and Ovarian Analysis of Disease Incidence and Carrier Estimation Algorithm
CDC | Centers for Disease Control and Prevention
CFHF | Comprehensive FH Form
CI | Confidence Interval
CR | Cancer Registry
CRC | Colorectal Cancer
CRIS | Cancer Risk Intake System
CVD | Cardio Vascular Disease
Cyr | Cyrillic
DOB | Date of Birth
DOR | Diagnostic Odds Ratio
DQ | Direct Question
EsPeR | Personalized Estimate of Risk
FAP | Familial Adenomatous Polyposis
FCAT | Familial Cancer Assessment Tool
FHAT | Family History Assessment Tool
FHQ | Family History Questionnaire
FHS | Family History Score
FHxT | Family History Tool
GCI | Genetic Counsellor interview
GI | Genetic Interview
GNI | Genetic Nurse Interview
GP | General Practitioner
GRACE | Genetic Risk Assessment in the Clinical Environment
GRAIDS | Genetic Risk Assessment in an Intranet and Decision Support trial
HBOCS | Hereditary Breast-Ovarian Cancer Syndrome
HNPCC | Hereditary Nonpolyposis Colorectal Cancer
IM | Internal Medicine
LFS | Li-Fraumeni Syndrome
LR- | Negative Likelihood Ratio
LR+ | Positive Likelihood Ratio
MR | Medical Records
N/A | Not Applicable.
NICE | National Institute for Clinical Excellence
NIDDM | Non-Insulin Dependent Diabetes Mellitus
NPV | Negative Predictive Value
NR | Not Reported
NSW | New South Wales
PAC | Probability of Agreement of Cancer
PANC | Probability of Agreement of No Cancer
PC | Primary Care
PCP | Primary Care Provider
PDA | Personal Digital Assistant
PMH | Past Medical History
PPV | Positive Predictive Values
PSI | Physician Structured Interview
Q | Question
QOL | Quality Of Life
RAGS | Risk Assessment in Genetics
RAT | Risk Assessment Tool
RCT | Randomized Controlled Trial
SD | Standard Deviation
SE | Standard Error
SRS | Systematic Review Software
TED | Thrombo-Embolic Disease
VS | Versus