# References

1 Acheson LS, Wiesner GL, Zyzanski SJ, et al. Family history-taking in community family practice: implications for genetic screening. Genet Med. May. 2000;2(3):180-5. [pmid: 11256663].
2 Yoon PW, Scheuner MT, Peterson-Oehlke KL, et al. Can family history be used as a tool for public health and preventive medicine?. Genet Med. Jul. 2002;4(4):304-10. [pmid: 12172397].
3 Rich EC, Burke W, Heaton CJ, et al. Reconsidering the family history in primary care. J Gen Intern Med. Mar. 2004;19(3):273-80. [pmid: 15009784]. [pmcid: 1492151].
4 Scheuner MT, Gordon OK. Genetic risk assessment for common diseases. In: Emery and Rimoin's Principal and Practice of Medical Genetics, 4th London: Churchill-Livingstone; 2002. p. 654–74.
5 Qureshi N, Modell B, Modell M. Timeline:Raising the profile of genetics in primary care. Nat Rev Genet. 2004;5(10):783-90. [pmid: 15510169].
6 Bennett, R. Is a universal family history tool feasible? The genetic family history in practice. http://www.nchpeg.org/newsletter/inpracticespr04.pdf
7 Kupfer SS, McCaffrey S, Kim KE. Racial and Gender Disparities in Hereditary Colorectal Cancer Risk Assessment: The Role of Family History. J Cancer Educ. 2006;21(Suppl 1):S32-S36. [pmid: 17020499].
8 Breuer B, Kash KM, Rosenthal G, et al. Reporting bilaterality status in first-degree relatives with breast cancer: a validity study. Genet Epidemiol. 1993;10(4):245-56. [pmid: 8224805].
9 Geller BM, Mickey RM, Rairikar CJ, et al. Identifying women at risk for inherited breast cancer using a mammography registry. J Cancer Educ. 2001;16(1):46-9. [pmid: 11270900].
10 Parent ME, Ghadirian P, Lacroix A, et al. Accuracy of reports of familial breast cancer in a case-control series. Epidemiology. 1995;6(2):184-6. [pmid: 7742408].
11 Parent M, Ghadirian P, Lacroix A, et al. The reliability of recollections of family history: implications for the medical provider. J Cancer Educ. 1997;12(2):114-20. [pmid: 9229275].
12 Schneider KA, DiGianni LM, Patenaude AF, et al. Accuracy of cancer family histories: comparison of two breast cancer syndromes. Genet Test. 2004;8(3):222-8. [pmid: 15727243].
13 Kerber RA, Slattery ML. Comparison of self-reported and database-linked family history of cancer data in a case-control study. Am J Epidemiol. 1997;146(3):244-8. [pmid: 9247008].
14 Mitchell RJ, Brewster D, Campbell H, et al. Accuracy of reporting of family history of colorectal cancer. Gut. 2004;53(2):291-5. [pmid: 14724166]. [pmcid: 1774933].
15 Gaff CL, Aragona C, MacInnis RJ, et al. Accuracy and completeness in reporting family history of prostate cancer by unaffected men. Urology. 2004;63(6):1111-6. [pmid: 15183962].
16 Katballe N, Juul S, Christensen M, et al. Patient accuracy of reporting on hereditary non-polyposis colorectal cancer-related malignancy in family members. Br J Surg. 2001;88(9):1228-33. [pmid: 11531872].
17 King TM, Tong L, Pack RJ, et al. Accuracy of family history of cancer as reported by men with prostate cancer. Urology. 2002;59(4):546-50. [pmid: 11927311].
18 Sijmons RH, Boonstra AE, Reefhuis J, et al. Accuracy of family history of cancer: clinical genetic implications. Eur J Hum Genet. 2000;8(3):181-6. [pmid: 10780783].
19 Aitken J, Bain C, Ward M, et al. How accurate is self-reported family history of colorectal cancer?. Am J Epidemiol. 1995;141(9):863-71. [pmid: 7717363].
20 Anton-Culver H, Kurosaki T, Taylor TH, et al. Validation of family history of breast cancer and identification of the BRCA1 and other syndromes using a population-based cancer registry. Genet Epidemiol. 1996;13(2):193-205. [pmid: 8722746].
21 Eerola H, Blomqvist C, Pukkala E, et al. Familial breast cancer in southern Finland: how prevalent are breast cancer families and can we trust the family history reported by patients?. Eur J Cancer. 2000;36(9):1143-8. [pmid: 10854948].
22 Gianz K, Grove J, Le Marchand L, et al. Underreporting of family history of colon cancer: Correlates and implications. Cancer Epidemiol Biomarkers Prev. 1999;8(7):635-9. [pmid: 10428202].
23 Theis B, Boyd N, Lockwood G, et al. Accuracy of family cancer history in breast cancer patients. Eur J Cancer Prev. 1994;3(4):321-7. [pmid: 7950886].
24 Ziogas A, Anton-Culver H. Validation of family history data in cancer family registries. Am J Prev Med. 2003;24(2):190-8. [pmid: 12568826].
25 Andrieu N, Launoy G, Guillois R, et al. Estimation of the familial relative risk of cancer by site from a French population based family study on colorectal cancer (CCREF study). Gut. 2004;53(9):1322-8. [pmid: 15306593]. [pmcid: 1774179].
26 Bruner DW, Baffoe-Bonnie A, Miller S, et al. Prostate cancer risk assessment program. A model for the early detection of prostate cancer. Oncology (Huntington). 1999;13(Huntington):325-34.
27 Chalmers KI, Luker KA, Leinster SJ, et al. Information and support needs of women with primary relatives with breast cancer: development of the Information and Support Needs Questionnaire. J Adv Nurs. 2001;35(4):497-507. [pmid: 11529948].
28 De Jong AE, Vasen HF. The frequency of a positive family history for colorectal cancer: a population-based study in the Netherlands. Netherlands Journal of Medicine. Nov. 2006;64(10):367-70. [pmid: 17122453].
29 Fletcher RH, Lobb R, Bauer MR, et al. Screening patients with a family history of colorectal cancer. J Gen Intern Med. Apr. 2007;22(4):508-13. [pmid: 17372801]. [pmcid: 1829437].
30 Green RC, Green JS, Buehler SK, et al. Very high incidence of familial colorectal cancer in Newfoundland: A comparison with Ontario and 13 other population-based studies. Familial Cancer. 2007;6(1):53-62. [pmid: 17039269].
31 Skinner CS, Rawl SM, Moser BK, et al. Impact of the Cancer Risk Intake System on patient-clinician discussions of tamoxifen, genetic counseling, and colonoscopy. J Gen Intern Med. Apr. 2005;20(4):360-5. [pmid: 15857495]. [pmcid: 1490091].
32 Tischkowitz M, Wheeler D, France E, et al. A comparison of methods currently used in clinical practice to estimate familial breast cancer risks. Ann Oncol. 2000;11(4):451-4. [pmid: 10847465].
33 Weinrich SP, Faison-Smith L, Hudson-Priest J, et al. Stability of self-reported family history of prostate cancer among African American men. J Nurs Meas. 2002;10(1):39-46. [pmid: 12048968].
34 Hlavaty T, Lukac L, Huorka M, et al. Positive family history promotes participation in colorectal cancer screening. Bratisl Lek Listy. 2005;106(10):318-23. [pmid: 16541612].
35 Quillin JM, Ramakrishnan V, Borzelleca J, et al. Paternal Relatives and Family History of Breast Cancer. Am J Prev Med. 2006;31(3):265-8. [pmid: 16905040].
36 Emery J, Morris H, Goodchild R, et al. The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. Br J Cancer. Aug 14. 2007;97(4):486-93. [pmid: 17700548].
37 Emery J. The GRAIDS Trial: the development and evaluation of computer decision support for cancer genetic risk assessment in primary care. Ann Hum Biol. 2005;32(2):218-27. [pmid: 16096220].
38 Emery J, Walton R, Coulson A, et al. Computer support for recording and interpreting family histories of breast and ovarian cancer in primary care (RAGs): qualitative evaluation with simulated patients. BMJ. 1999;319(7201):32-6. [pmid: 10390458]. [pmcid: 28153].
39 Emery J, Walton R, Murphy M, et al. Computer support for interpreting family histories of breast and ovarian cancer in primary care: comparative study with simulated cases. BMJ. 2000;321(7252):28-32. [pmid: 10875832]. [pmcid: 27423].
40 Colombet I, Dart T, Leneveut L, et al. Combining risks estimations and clinical practice guidelines in a computer decision aid: a pilot study of the EsPeR system. Stud Health Technol Inform. 2003;95:525-30. [pmid: 14664040].
41 Colombet I, Dart T, Leneveut L, et al. A computer decision aid for medical prevention: a pilot qualitative study of the Personalized Estimate of Risks (EsPeR) system. BMC Med Inform Decis Mak. 2003;3:13. [pmid: 14641924]. [pmcid: 317339].
42 Acheson LS, Zyzanski SJ, Stange KC, et al. Validation of a self-administered, computerized tool for collecting and displaying the family history of cancer. J Clin Oncol. Dec 1. 2006;24(34):5395-402. [pmid: 17088568].
43 Benjamin C, Booth K, Ellis I. A Prospective Comparison Study of Different Methods of Gathering Self-Reported Family History Information for Breast Cancer Risk Assessment. J Genet Couns. Apr. 2003;12(2):151-70.
44 Braithwaite D, Sutton S, Mackay J, et al. Development of a risk assessment tool for women with a family history of breast cancer. Cancer Detect Prev. 2005;29(5):433-9. [pmid: 16055276].
45 Fisher TJ, Kirk J, Hopper JL, et al. A simple tool for identifying unaffected women at a moderately increased or potentially high risk of breast cancer based on their family history. Breast. 2003;12(2):120-7. [pmid: 14659341].
46 Frezzo TM, Rubinstein WS, Dunham D, et al. The genetic family history as a risk assessment tool in internal medicine. Genet Med. 2003;5(2):84-91. [pmid: 12644777].
47 Grover S, Stoffel EM, Bussone L, et al. Physician assessment of family cancer history and referral for genetic evaluation in colorectal cancer patients. Clin Gastroenterol Hepatol. 2004;2(9):813-9. [pmid: 15354282].
48 House W, Sharp D, Sheridan E. Identifying and screening patients at high risk of colorectal cancer in general practice. J Med Screen. 1999;6(4):205-8. [pmid: 10693067].
49 Qureshi N, Bethea J, Modell B, et al. Collecting genetic information in primary care: evaluating a new family history tool. Fam Pract. Dec. 2005;22(6):663-9. [pmid: 16055464].
50 Sweet KM, Bradley TL, Westman JA. Identification and referral of families at high risk for cancer susceptibility. J Clin Oncol 2002 Jan 2;(2):
51 Kelly KM, Shedlosky-Shoemaker R, Porter K, et al. Cancer family history reporting: Impact of method and psychosocial factors. Journal of Genetic Counseling. 2007;16(3):373-82. [pmid: 17318453].
52 Murff HJ, Greevy RA, Syngal S. The comprehensiveness of family cancer history assessments in primary care. Community Genetics. 2007;10(3):174-80. [pmid: 17575462].
53 Yang Q, Khoury MJ, Rodriguez C, et al. Family history score as a predictor of breast cancer mortality: Prospective data from the cancer prevention study II, United States, 1982- 1991. Am J Epidemiol. 1998;147(7):652-9. [pmid: 9554604].
54 Hughes KS, Roche C, Campbell CT, et al. Prevalence of family history of breast and ovarian cancer in a single primary care practice using a self-administered questionnaire. Breast J. 2003;9(1):19-25. [pmid: 12558666].
55 Hurt GJ, McQuellon RP, Michielutte R, et al. Risk assessment of first-degree relatives of women with breast cancer: a feasibility study. Oncol Nurs Forum. 2001;28(7):1097-104. [pmid: 11517843].
56 de Bock GH, Perk DC, Oosterwijk JC, et al. Women worried about their familial breast cancer risk—a study on genetic advice in general practice. Fam Pract. Feb. 1997;14(1):40-3. [pmid: 9061343].
57 Schroy PC, Glick JT, Geller AC, et al. A novel educational strategy to enhance internal medicine residents' familial colorectal cancer knowledge and risk assessment skills. Am J Gastroenterol. 2005;100(3):677-84. [pmid: 15743368].
58 Gramling R, Duffy C, David S. Does providing hereditary breast cancer risk assessment support to practicing physicians decrease the likelihood of them discussing such risk with their patients?. Genet Med. 2004;6(6):542. [pmid: 15545753].
59 Gilpin CA, Carson N, Hunter AG. A preliminary validation of a family history assessment form to select women at risk for breast or ovarian cancer for referral to a genetics center. Clin Genet. 2000;58(4):299-308. [pmid: 11076055].
60 Watson E, Clements A, Yudkin P, et al. Evaluation of the impact of two educational interventions on GP management of familial breast/ovarian cancer cases: a cluster randomised controlled trial. Br J Gen Pract. 2001;51(471):817-21. [pmid: 11677705]. [pmcid: 1314127].
61 Watson E, Clements A, Lucassen A, et al. Education improves general practitioner (GP) management of familial breast/ovarian cancer: findings from a cluster randomised controlled trial. J Med Genet. Oct. 2002;39(10):779-81. [pmid: 12362040]. [pmcid: 1734993].
62 Wilson BJ, Torrance N, Mollison J, et al. Cluster randomized trial of a multifaceted primary care decision-support intervention for inherited breast cancer risk. Fam Pract. Oct. 2006;23(5):537-44. [pmid: 16787957].
63 Wilson BJ, Torrance N, Mollison J et al. Improving the referral process for familial breast cancer genetic counselling: findings of three randomised controlled trials of two interventions. Health Technol Assess, 9 (3). The NHS Health Technology Assessment Programme; 2005.
64 Johnson N, Lancaster T, Fuller A, et al. The prevalence of a family history of cancer in general practice. Fam Pract. Sep. 1995;12(3):287-9. [pmid: 8536831].
65 Trepanier A, Ahrens M, McKinnon W, et al. Genetic cancer risk assessment and counseling: recommendations of the national society of genetic counselors. J Genet Couns. Apr. 2004;13(2):83-114. [pmid: 15604628].
66 Johns LE, Houlston RS. A systematic review and meta-analysis of familial colorectal cancer risk. Am J Gastroenterol. Oct. 2001;96(10):2992-3003. [pmid: 11693338].
67 Sandhu MS, Luben R, Khaw KT. Prevalence and family history of colorectal cancer: implications for screening. J Med Screen. 2001;8(2):69-72. [pmid: 11480446].
68 Claus EB, Risch NJ, Thompson WD. Age at onset as an indicator of familial risk of breast cancer. Am J Epidemiol. Jun. 1990;131(6):961-72. [pmid: 2188501].
69 Mettlin C, Croghan I, Natarajan N, et al. The association of age and familial risk in a case-control study of breast cancer. Am J Epidemiol. Jun. 1990;131(6):973-83. [pmid: 2343868].
70 Offit K, Brown K. Quantitating familial cancer risk: a resource for clinical oncologists. J Clin Oncol. Aug. 1994;12(8):1724-36. [pmid: 8040684].
71 U.S.Preventive Services Task Force. Genetic Risk Assessment and BRCA Mutatiion Testing for Breast and Ovarian Cancer Susceptibility: Recommendation Statement. Ann Intern Med. 2005;143:355-61. [pmid: 16144894].
72 McIntosh A, Shaw C, Evans G et al. Clinical Guidelines and Evidence Review for the Classification and Care of Women at Risk of Familial Breast Cancer. Clinical Guideline 14. National Collaborating Centre for Primary Care/University of Sheffield, London: National Institute for Clinical Excellence; 2004.
73 Winawer S, Fletcher R, Rex D, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale-Update based on new evidence. Gastroenterology. Feb. 2003;124(2):544-60. [pmid: 12557158].
74 Struewing JP, Hartge P, Wacholder S, et al. The risk of cancer associated with specific mutations of BRCA1 and BRCA2 among Ashkenazi Jews. N Engl J Med. May 15. 1997;336(20):1401-8. [pmid: 9145676].
75 Moslehi R, Chu W, Karlan B, et al. BRCA1 and BRCA2 mutation analysis of 208 Ashkenazi Jewish women with ovarian cancer. Am J Hum Genet. Apr. 2000;66(4):1259-72. [pmid: 10739756]. [pmcid: 1288193].
76 Satagopan JM, Offit K, Foulkes W, et al. The lifetime risks of breast cancer in Ashkenazi Jewish carriers of BRCA1 and BRCA2 mutations. Cancer Epidemiol Biomarkers Prev. May. 2001;10(5):467-73. [pmid: 11352856].
77 Warner E, Foulkes W, Goodwin P, et al. Prevalence and penetrance of BRCA1 and BRCA2 gene mutations in unselected Ashkenazi Jewish women with breast cancer. J Natl Cancer Inst. Jul 21. 1999;91(14):1241-7. [pmid: 10413426].
78 Cole J, Conneally PM, Hodes ME, et al. Genetic family history questionnaire. J Med Genet. Feb. 1978;15(1):10-8. [pmid: 633315]. [pmcid: 1012815].
79 Bernhardt BA, Pyeritz RE. The economics of clinical genetics services. III. Cognitive genetics services are not self-supporting. Am J Hum Genet. Feb. 1989;44(2):288-93. [pmid: 2912071]. [pmcid: 1715403].
80 Watson EK, Shickle D, Qureshi N, et al. The ‘new genetics’ and primary care: GPs' views on their role and their educational needs. Fam Pract. Aug. 1999;16(4):420-5. [pmid: 10493715].
81 Napier JA, Metzner H, Johnson BC. Limitations of morbidity and mortality data obtained from family histories—a report from the Tecumseh community health study. Am J Public Health. Jan. 1972;62(1):30-5. [pmid: 5008635]. [pmcid: 1529994].
82 Davies NJ, Sham PC, Gilvarry C, et al. Comparison of the family history with the family study method: report from the Camberwell Collaborative Psychosis Study. Am J Med Genet. Feb 21. 1997;74(1):12-7. [pmid: 9033999].
83 Desai MM, Bruce ML, Desai RA, et al. Validity of self-reported cancer history: a comparison of health interview data and cancer registry records. Am J Epidemiol. Feb 1. 2001;153(3):299-306. [pmid: 11157418].
84 Roy MA, Walsh D, Kendler KS. Accuracies and inaccuracies of the family history method: a multivariate approach. Acta Psychiatr Scand. Apr. 1996;93(4):224-34. [pmid: 8712019].
85 Zhu K, McKnight B, Stergachis A, et al. Comparison of self-report data and medical records data: results from a case-control study on prostate cancer. Int J Epidemiol. Jun. 1999;28(3):409-17. [pmid: 10405842].
86 Bondy ML, Strom SS, Colopy MW, et al. Accuracy of family history of cancer obtained through interviews with relatives of patients with childhood sarcoma. J Clin Epidemiol. Jan. 1994;47(1):89-96. [pmid: 8283198].
87 Murff HJ, Spigel DR, Syngal S. Does this patient have a family history of cancer? An evidence-based analysis of the accuracy of family cancer history. JAMA. Sep 22. 2004;292(12):1480-9. [pmid: 15383520].
88 Lucassen A, Watson E, Harcourt J, et al. Guidelines for referral to a regional genetics service: GPs respond by referring more appropriate cases. Fam Pract. Apr. 2001;18(2):135-40. [pmid: 11264262].
89 Rose PW, Murphy M, Munafo M, et al. Improving the ascertainment of families at high risk of colorectal cancer: a prospective GP register study. Br J Gen Pract. 2004;54(501):267-71. [pmid: 15113493]. [pmcid: 1314851].
90 Ebell MH, Heaton CJ. Development and evaluation of a computer genogram. J Fam Pract. Nov. 1988;27(5):536-8. [pmid: 3193069].
91 Scheuner MT, Wang SJ, Raffel LJ, et al. Family history: A comprehensive genetic risk assessment method for the chronic conditions of adulthood. Am J Med Genet. 1997;71(3):315-24. [pmid: 9268102].
92 McIntosh A, Shaw C, Evans G et al. Clinical Guidelines and Evidence Review for the Classification and Care of Women at Risk of Familial Breast Cancer. NICE CG014. London: National Institute for Clinical Excellence (NICE), National Collaborating Centre for Primary Care (NCCPC),University of Sheffield.; 2004.
93 Harvard Center for Cancer Prevention. Your Disease Risk: Cancer. President and Fellows of Harvard College. www.yourdiseaserisk.harvard.edu/hccpquiz.pl?lang+english&func=home&page=cancerindex.2005
94 Center for Disease Control. Family History for Preventive Medicine and Public Health. Centers for Disease Control and Prevention. www.cdc.gov/genomics/activities/FHx/fHixfs.htm
95 Enhancing the oversight of genetic tests: recommendations of the SACGT. Secretary's Advisory Committee on Genetic Testing, Baltimore, Maryland: National Institutes of Health, Department of Health and Human Services; 2000.
96 Yoon PW, Scheuner MT, Khoury MJ. Research priorities for evaluating family history in the prevention of common chronic diseases. Am J Prev Med. Feb. 2003;24(2):128-35. [pmid: 12568818].
97 Liu JLY, Wyatt JC, Deeks JJ et al. Systematic reviews of clinical decision tools for acute abdominal pain. Vol 10: No. 47. Tunbridge Wells, Kent. UK: Gray Publishing; 2006.
98 Berry DA, Iversen ESJ, Gudbjartsson DF, et al. BRCAPRO validation, sensitivity of genetic testing of BRCA1/BRCA2, and prevalence of other breast cancer susceptibility genes. J Clin Oncol. 2002;20(11):2701-12. [pmid: 12039933].
99 Antoniou AC, Gayther SA, Stratton JF, et al. Risk models for familial ovarian and breast cancer. Genet Epidemiol. 2000;18(2):173-90. [pmid: 10642429].
100 Vasen HF, Watson P, Mecklin JP, et al. New clinical criteria for hereditary nonpolyposis colorectal cancer (HNPCC, Lynch syndrome) proposed by the International Collaborative group on HNPCC. Gastroenterology. 1999;116(6):1453-6. [pmid: 10348829].
101 Evans DG, Eccles DM, Rahman N, et al. A new scoring system for the chances of identifying a BRCA1/2 mutation outperforms existing models including BRCAPRO. J Med Genet. 2004;41(6):474-80. [pmid: 15173236]. [pmcid: 1735807].
102 Murff HJ, Spigel DR, Syngal S. Does this patient have a family history of cancer? An evidence-based analysis of the accuracy of family cancer history. JAMA. 2004;292(12):1480-9. [pmid: 15383520].
103 Whiting P, Rutjes AWS, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol 2003;3(25):
104 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
105 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. Jun. 1998;52(6):377-84. [pmid: 9764259]. [pmcid: 1756728].
106 Horvath AR, Pewsner D. Systematic reviews in laboratory medicine: principles, processes and practical considerations. Clin Chim Acta. Apr. 2004;342(12):23-39. [pmid: 15026264].
107 American Academy of Family Practice. Family History Tool. American Academy of Family Practice. http://www.genetests.org/servlet/access?id=8888892&key=xdmglBahsKytS&fcn=y&fw=qgJE&filename=/tools/concepts/medHist.html
108 U.S.Surgeon General. My Family Health Portrait. U.S.Department of Health & Human Services, Office of the Surgeon General. http://www.hhs.gov/familyhistory/downloads/portraitEng.pdf
109 Oremus M, Wolfson C, Perrault A, et al. Interrater reliability of the modified Jadad quality scale for systematic reviews of Alzheimer's disease drug trials. Dement Geriatr Cogn Disord. May. 2001;12(3):232-6. [pmid: 11244218].
110 Guttmacher AE, Collins FS, Carmona RH. The family history—more important than ever. N Engl J Med. Nov 25. 2004;351(22):2333-6. [pmid: 15564550].
111 Carmona RH, Wattendorf DJ. Personalizing prevention: the U.S. Surgeon General's Family History Initiative. Am Fam Physician. Jan 1. 2005;71(1):36-39. [pmid: 15663022].
112 Benkendorf, J., Bodurtha, J., and Schreiber, A. Virginia is for family history lovers. The genetic family history in practice. http://www.nchpeg.org/newsletter/inpracticespr05.pdf
113 Norwich Union. Norwich Union Health Tree. Norwich Union. http://www.norwichunion.com/healthtree/index.htm
114 American Medical Association. AMA Adult Family History Form. American Medical Association. http://www.ama-assn.org/ama/pub/category/13333.html
115 Bennett RL, Hudgins L, Smith CO, et al. Inconsistencies in genetic counseling and screening for consanguineous couples and their offspring: the need for practice guidelines. Genet Med. Sep. 1999;1(6):286-92. [pmid: 11258630].
116 Bennett RL. The Practical Guide to the Genetic Family History. New York: John Wiley & Sons; 1999.
117 Qureshi N, Kai J. Genomic medicine for underserved minority populations in family medicine. Am Fam Physician. Aug 1. 2005;72(3):386-7. [pmid: 16100853].
118 Sheldon TA, Cullum N, Dawson D, et al. What's the evidence that NICE guidance has been implemented? Results from a national evaluation using time series analysis, audit of patients' notes, and interviews. BMJ. 2004;329(7473):999-1003. [pmid: 15514342]. [pmcid: 524545].
119 Lynch HT. Cancer family history and genetic testing: are malpractice adjudications waiting to happen?. Am J Gastroenterol. Mar. 2002;97(3):518-20. [pmid: 11922540].
120 Campbell M, Fitzpatrick R, Haines A, et al. Framework for design and evaluation of complex interventions to improve health. BMJ. Sep 16. 2000;321(7262):694-6. [pmid: 10987780]. [pmcid: 1118564].
121 Kawamoto K, Houlihan CA, Balas EA, et al. Improving clinical practice using clinical decision support systems: a systematic review of trials to identify features critical to success. BMJ. Apr 2. 2005;330(7494):765. [pmid: 15767266]. [pmcid: 555881].
122 Summerton N, Garrood PV. The family history in family practice: a questionnaire study. Fam Pract. Aug. 1997;14(4):285-8. [pmid: 9283847].
123 Fry A, Campbell H, Gudmunsdottir H, et al. GPs' views on their role in cancer genetics services and current practice. Fam Pract. Oct. 1999;16(5):468-74. [pmid: 10533942].
124 Elwyn G, Gray J, Iredale R. Tensions in implementing the new genetics - General practitioners in south Wales are unconvinced of their role in genetics services. BMJ. Jul 22. 2000;321(7255):240-1. [pmid: 10979686].
125 Hyland F, Kinmonth AL, Marteau TM, et al. Raising concerns about family history of breast cancer in primary care consultations: prospective, population based study. Women's Concerns Study Group. BMJ. Jan 6. 2001;322(7277):27-8. [pmid: 11141150]. [pmcid: 26605].