# Acknowledgments

We are grateful to our Task Order Officer, Gurvaneet Randhawa, and members of the Technical Expert Panel who were instrumental in developing the questions and defining the scope of this review: Ralph J. Coates, Paula W. Yoon, Dejana Braithwaite, Gareth Evans, Caryl J. Heaton, Lisa Madlensky, Harvey J. Murff, and Suzanne O'Neill.

We would like to thank the following people who helped with the data abstraction for this review: Connie Freeborn, Nofisa Ismaila, Jennifer Merriam, and Paula Robinson. We would like to thank Mark Oremus for his comments on the report.

Our editorial and review staff, Fulvia Baldassarre, Lynda Booker, Roxanne Cheeseman, Mary Gauld, Maureen Rice, Cecile Royer, and Sarah Smith have provided invaluable input into this document.