# Introduction

## Importance of Family History Collection for Cancer Risk Evaluation

A positive family history is a risk factor for many chronic diseases, reflecting “the consequences of genetic susceptibilities, shared environment, and common behaviors”.^2^ The systematic collection and assessment of family history information is a potentially valuable tool in preventive medicine, and is crucial in the identification of genetic risk.^1^ In some situations, family history information alone can form the basis for offering patients appropriately tailored preventive interventions.^2,^ ^3^ In addition, the clinical predictive value of even the most accurate DNA test is strongly influenced by prior probability—such as a positive family history.^4^ For example, Rich and colleagues^3^ illustrated how the positive predictive value of the same DNA-based test for familial adenomatous polyposis (FAP) could rise from about 11 percent in a patient where no family history information was available to over 99 percent if the patient accurately reported FAP in just one sibling or parent. Thus, family history information is potentially useful both as a clinical tool in its own right, and also as an important adjunct to DNA-based testing.

Cancers are a group of relatively common conditions in which, for at least some, family history appears to be an important risk factor. A British study suggested that a typical UK family physician with 2,000 patients would expect up to 50 of those aged 35 to 64 to have a history of familial cancer, and 30 to 40 patients meriting some form of active preventive surveillance.^64^ Cancer family histories can broadly be divided into three categories: hereditary, familial, and sporadic.^65^ Hereditary cancers are predominantly single gene disorders with Mendelian patterns of inherited risk. Familial cancers describe other less obvious clusters of cancer within families, thought to be due to combinations of multiple low penetrance gene mutations with or without contributions from shared environmental and/or behavioral risk factors. Sporadic cancers are those which occur without an apparent hereditary or familial pattern.

This report focuses on four cancer types: breast, ovarian, prostate, and colorectal. These are some of the most common cancers where the role of family history is widely recognized as a risk factor.^66^–^70^ For each of them, the contribution of familial risk is reflected in evidence-based consensus statements^71^–^73^ (e.g., http://www.ahrq.gov/clinic/uspstfix.htm). In some families, these cancers form part of recognized hereditary syndromes; for example, BRCA1 mutations increase familial risk of breast, ovarian and prostate cancer while MLH1, MSH2, and other DNA mismatch repair genes increase the familial risk of colorectal, endometrial, ovary, small bowel, and pancreatic cancers, among others.^65^ In some cases, ethnic ancestry is also associated with risk of cancer-associated genetic mutation, such as breast cancer in the Ashkenazi Jewish community.^74^–^77^

### Primary Care Physicians and Cancer Risk Assessment and Management

Primary care providers (PCPs) have always used family history information as a core tool for their practice,^5^ well before the arrival of the “genomics age”. However, the increasing emphasis on identifying and managing genetic susceptibility, and the question of what might now be considered an “adequate” family history for this purpose, presents real challenges for PCPs.^6^ While a genetics specialist may be able, indeed advised, to devote substantial time to eliciting and confirming family history data (on the order of several hours)^65,^ ^78,^ ^79^ family physicians, internists, and other non-genetics providers may have only minutes. Other barriers to more than a “minimal” approach include unfavorable reimbursement policies, pressure from colleagues and patients to focus on other aspects of care, perceived lack of skills, and lack of confidence.^3,^ ^80^ Conversely, family physicians and other PCPs may be able to capture family history data over time, and are well placed to keep such information up to date.

The use of family history information to make preventive and clinical management decisions also depends on the adequacy of providers' knowledge, skills and confidence; this is extremely challenging in a field where the knowledge base is rapidly evolving. To complement more general educational interventions, there is a strong case for the development of effective tools, designed for use in primary care settings, which permit providers to translate an individual's family history data into meaningful risk stratification, with linkage to evidence-based guidance on appropriate preventive and clinical management interventions. Thus, the translation of family history information into improved health outcomes depends on the availability and integrated use of effective interventions for data capture, risk assessment, and clinical intervention.

### Accuracy of Family History Reporting

In order for family history to be of value in clinical decision making, patients must possess, and PCPs must be able to ascertain, accurate family health information. Assessing accuracy requires a clear idea of an appropriate gold standard—what patients “should” know, and what clinicians “should” be able to obtain. In simple terms, an “accurate” family history could be considered to be one which is sensitive (disease in relatives is correctly identified) and specific (lack of disease in relatives is correctly identified). Work in the field of psychiatry has suggested three gold standards for studies of family history taking: an “ideal” standard, based on comprehensive data obtained from the relatives, hospital and physician records and/or disease registers;^81^–^83^ a “best estimate diagnosis” (BED) standard,^84^ based on best available data from death certificates and medical records;^65,^ ^85,^ ^86^ and a “pragmatic BED”, based on the family history obtainable in a detailed interview conducted by a trained clinical genetics professional. Our consultation with the key stakeholders in this review has indicated that an appropriate practical gold standard for evaluating accuracy would be information obtained directly from relatives' medical records, cancer registries, and/or death certificates. Such information should be used both to confirm reported cases of cancer in the family, and to confirm absence of a cancer diagnosis in relatives who were reported not to have cancer.^87^

### Collection of Family History in Primary Care

There is no single agreed-upon approach to guide primary care practitioners in taking a genetic family history within office consultations (which are often brief). Family history taking can be conducted as part of a disease specific approach which aims to identify risk of selected single gene disorders (e.g., hereditary breast or colon cancer) for the purpose of ensuring appropriate specialist intervention.^88,^ ^89^ Alternatively, it can be directed more broadly towards identifying possible risk of a number of common multi-factorial disorders such as cancer, diabetes, and coronary heart disease.^46,^ ^49^

Family history data may be recorded as notes or lists within patient charts, represented as family trees or genetic pedigrees, or stored within computer databases which can be linked to decision support systems. In the last few years several computer-based pedigree drawing packages have been developed, such as genogram software.^38,^ ^90^ It is not clear whether such approaches translate well from specialist use to application in primary care.

There is also no consensus on the extent or detail of family history information which needs to be recorded in primary care, compared with specialist genetics settings. The extent of cancer family history collection has to be adequate to enable PCPs to make appropriate clinical and prevention decisions, but it is not clear whether this necessarily requires the same approach as that used by a genetics specialist.^3^

### Risk Assessment in Primary Care

There are several issues which may influence the translation of family history information into meaningful risk assessment for patients. These include the level of complexity of family history information which is actually required for risk assessment for any given disorder, the validity of risk stratification guidelines or algorithms, the kind of tools that exist to facilitate risk stratification, (and their effectiveness in practice), and the actual predictive value of risk assessment tools (RATs).

At its most simple, assessing familial risks associated with common adult-onset diseases requires setting a threshold where the family history indicates a cause for suspicion (i.e., dichotomizing risk into reassuring the patient or recommending further action). A more complex approach is to separate risk into three or more strata (e.g., “high”, “moderate” and “average”).^91,^ ^92^ In general terms, individuals at “average” risk (the risk level of the general population) would be offered standard preventive advice, those at “moderate” risk would be offered a higher level of intervention, such as more extensive or more frequent surveillance, and those at “high” risk would usually be referred for specialist assessment and possibly considered for mutation testing.^2^

Risk assessment tools need to be valid, in terms of their clinical predictive value, but they must also be feasible for use in the intended settings, and generate benefits in the process or outcome of care when compared with current practice. Feasibility and effectiveness in practice may be influenced by the actual implementation format; for example, a risk stratification protocol could be presented in paper-and-pencil format, on a personal digital assistant, or on the desktop in a web-based format. Such tools may be passively disseminated, or accompanied by educational interventions and/or ongoing support from genetics professionals. Recent examples of web-based tools include Harvard's “Your Disease Risk”^93^ and the Centers for Disease Control's (CDC) Family HealthWare.^94^

### The ACCE Framework

Tools for family history collection and risk assessment lend themselves to evaluation using the framework developed for genetic predictive testing by the Secretary's Advisory Committee on Genetic Testing.^95^ This framework (see Table 1, derived from Yoon 2003), widely referred to as the “ACCE” framework, comprises four evaluative elements: analytic validity, clinical validity, clinical utility, and ethical legal and social issues.^2,^ ^96^

Table 1 Application of the ACCE framework^96^ to family history as a screening tool

Element | Definition | Components
Analytic validity | An indicator of how well a family history tool measures the characteristic (“family history”) that it is intended to measure | Analytical sensitivity and specificity
Clinical validity | A measurement of the accuracy with which a RAT based on family history information predicts disease risk | Clinical sensitivity and specificity
| | Positive and negative predictive values
Clinical utility | The degree to which benefits are provided by using a clinically valid RAT based on family history information | Availability of effective preventive and clinical interventions
| | Health risks and benefits of preventive and clinical interventions
| | Health risks and benefits of family history and RATs
| | Economic assessment
Ethical, legal, and social implications | Issues affecting data collection and interpretation that might negatively impact individuals, families and societies | Stigmatization
| | Discrimination
| | Psychological harm Risks to privacy and confidentiality

Yoon P.W., Scheuner M.T., Khoury M.J. Research priorities for evaluating family history in the prevention of common chronicdiseases. Am J Prev Med 2003;23 (2):128–135.

Thus, in terms of family history, analytic validity describes the ability of a family history tool to correctly identify the pertinent information on disease in relatives. This is dependent on the effectiveness of a tool in promoting acquisition of appropriate family history data, and also on the ability of an informant to provide accurate information. Clinical validity describes the ability of a RAT to use valid family history data to correctly predict or stratify cancer risk in the informant. Risk assessment tools may vary in their complexity, from simply identifying an elevated cancer risk in the family, to more detailed risk prediction scores—but all are dependent on valid risk stratification criteria. An effective risk prediction tool therefore depends on a valid family history tool, and may or may not also take account of non-genetic factors which modify disease risk. Clinical utility considers the evidence that family history assessment, risk stratification, and subsequent preventive or clinical interventions actually bring overall health benefit to the individual patient. The ethical, legal, and social issues component of the framework considers the impact and consequences of using a family history based approach from a broader societal perspective.

The aim of this review is provide a partial contribution to the evidence base underlying analytic validity (the ability of a tool to capture accurate family history data) and clinical validity (the ability of a RAT to correctly predict disease risk). The main focus is on describing the availability and format of available family history and RATs, and the evidence that these are more effective than current practice in promoting accurate family history collection and assessment in primary care and population settings. It is not within the scope of the review to assess either the evidence underlying risk stratification systems (i.e., the predictive value of guidelines or criteria), or the evidence that preventive or clinical interventions based on such stratification provide overall benefit to patients (i.e., clinical utility). However, the evidence assembled in this review is a crucial element of determining how best to capture and use family history information in primary care to promote the anticipated population health benefits.

## Scope and Purpose of the Systematic Review

This systematic review addresses three research questions relating to the clinical utility of ascertaining family history as follows:

1 What is the evidence that patients or members of the public accurately know and report their family history of each one of, or a combination of, the following cancers: breast, ovarian, prostate, and colorectal?
2 How well do the different systematic family history collection forms and tools, such as take home tools, web based tools, etc., improve non-systematic approaches to family history collection by PCPs?
  a Identify tools intended to improve family history collection by PCPs.
  b Compare these tools against current practice.
3 What tools exist to enable PCPs to calculate, interpret, and act upon family history based risk information, and how well do these tools perform? For each cancer of interest:
  a Identify tools designed to facilitate calculation and/or interpretation of family history based risk information, with the purpose of promoting recommended clinical actions.
  b Assess the evidence for effectiveness of these tools in facilitating calculating and/or interpretation of family history based information.
  c Assess the evidence for effectiveness of these tools in promoting recommended clinical actions.
  d For each tool, identify the evidence base for each recommendation.