# Appendix E. Technical Expert Panel and Peer Reviewers

## Task Order Officer

- Gurvaneet Randhawa, MD, MPH
- Center for Outcomes and Evidence (COE)
- Agency for Healthcare Research and Quality
- Rockville, Maryland USA

## Partners from CDC

- Ralph J. Coates, PhD
- Associate Director for Science, Division of Cancer Prevention and Control
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention
- Atlanta, Georgia USA

- Paula W. Yoon, ScD, MPH
- National Office of Public Health Genomics
- Centers for Disease Prevention and Control
- Atlanta, Georgia USA

## Technical Expert Panel

- Dejana Braithwaite, PhD, MSc
- Carol Franck Buck Breast Care Center
- University of California Comprehensive Cancer Center
- San Francisco, California USA

- Gareth Evans, MB, BS, MD, FRCP
- Professor in Medical Genetics and Cancer Epidemiology
- Department of Clinical Genetics,
- St. Mary's Hospital, Whitworth Park
- Manchester, UK

- Caryl J. Heaton, DO
- Associate Professor and Vice-Chair of Family Medicine
- New Jersey Medical School, University of Medicine & Dentistry of New Jersey
- Newark, New Jersey USA

- Lisa Madlensky, PhD
- Assistant Professor, Family and Preventive Medicine
- Moores Cancer Center
- University of California, San Diego Medical Center
- La Jolla, California USA

- Harvey J. Murff, MD, MPH
- Assistant Professor of Medicine
- Vanderbilt Epidemiology Center
- Vanderbilt University Medical Center,
- Nashville, Tennessee USA

- Suzanne O'Neill, PhD, CGC
- Clinical Researcher and Genetic Counselor
- Evanston Northwestern Healthcare Center for Medical Genetics
- Research Assistant Professor, Northwestern University
- Feinberg School of Medicine
- Evanston, Illinois USA

## Peer Reviewers of the Report

- Louise Acheson, MD, MS
- Professor of Family Medicine, Oncology, and Reproductive Biology
- Case Western Reserve University,
- Cleveland, Ohio USA

- Joann A. Boughman, PhD.
- Executive Vice President
- American Society of Human Genetics
- Bethesda, Maryland USA

- Dejana Braithwaite, PhD, MSc
- Carol Franck Buck Breast Care Center
- University of California Comprehensive Cancer Center
- San Francisco, California USA

- Kathleen A. Calzone, RN, MSN, APNG
- National Cancer Institute
- Center for Cancer Research, Genetics Branch
- Bethesda, Maryland USA

- Gareth Evans, MB, BS, MD, FRCP
- Professor in Medical Genetics and Cancer Epidemiology
- Department of Clinical Genetics,
- St. Mary's Hospital, Whitworth Park
- Manchester, UK

- W. Greg Feero, MD, PhD
- Senior Advisor to the Director for Genomic Medicine
- National Human Genome Research Institute
- Bethesda, Maryland USA

- Jonathon Gray, MBChB, MRCP, PhD, FRCP
- Director, Wales Centre for Health
- Cardiff, Wales UK

- Joy Larsen Haidle, MS, CGC.
- Genetic Counselor, Hubert H. Humphrey Cancer Center
- Robbinsdale, Minnesota USA
- On behalf of the National Society of Genetic Counselors

- Lisa Madlensky, PhD
- Assistant Professor, Family and Preventive Medicine, Moores Cancer Center
- University of California, San Diego Medical Center
- La Jolla, California USA

- Phuong Mai, MD
- National Cancer Institute
- Division of Cancer Epidemiology and Genetics
- Rockville, Maryland USA

- Paul Metzer, MD, PhD
- Cancer Genetics Branch, Section of Molecular Cytogenetics
- National Human Genome Research Institute
- Bethesda, Maryland USA

- Harvey J. Murff, MD, MPH
- Assistant Professor of Medicine, Vanderbilt Epidemiology Center
- Vanderbilt University Medical Center
- Nashville, Tennessee USA

- Suzanne O'Neill, PhD, CGC
- Clinical Researcher and Genetic Counselor
- Evanston Northwestern Healthcare Center for Medical Genetics
- Research Assistant Professor, Northwestern University, Feinberg School of Medicine
- Evanston, Illinois USA

- Nancie Petrucelli, MS, CGC
- Cancer Genetic Counseling Service
- Barbara Ann Karmanos Cancer Institute
- Detroit, Michigan USA
- On behalf of the National Society of Genetic Counselors

- Mark E. Robson, MD
- Associate Attending Physician, Memorial Sloan-Kettering Cancer Center
- New York, NewYork USA
- On behalf of the American Society of Clinical Oncology

- Maren T. Scheuner, MD, MPH, FACMG
- RAND Corporation
- Department of Social & Health Sciences
- Santa Monica, California USA

- Eila Watson, PhD
- School of Health and Social Care
- Oxford Brookes University
- Oxford UK