# Appendix C. Evidence Tables

Table 1 Characteristics of studies focusing on the accuracy of reporting cancer family history

Author, Year, Country | Study Design and Criterion Standard | Study Population, Cancer Site and Clinical setting | Method of Family History Information Collection | Relatives Characteristics and Methods Used to Validate Family History
Acheson^1^ 2006 | Study design: Case series | Patients: Patients scheduled for genetics consultation at university genetics centre | Method of collection: Computerized tool “Genetic Risk Easy Assessment Tool (GREAT)” and compared to face to face interview | Relatives characteristics: First degree relatives
Australia | Criterion standard: Interview with geneticist | Age: Mean 40 years (SD 12) | Medium: Paper and electronic | Affected relatives: Not verified due to reliability study
| | Cancer site: Cancer free and cancer not specified | Format: Pedigree format | Unaffected relatives: Not verified due to reliability study
| | Setting: Genetics counseling centre
Aitken^2^ 1995 | Study design: Case control | Patients: Patients undergoing colonoscopy at a teaching hospital; cases had hyperplastic or adenomatous polyp diagnosed at colonoscopy; controls were free of polyps | Method of collection: Mail survey | Relatives characteristics: First degree relatives
Australia | Criterion standard: Relatives self report; relatives doctors report; pathology reports; information from hospitals and death certificates | Age: 20 to 75 years | Medium: Paper | Affected relatives: Medical records; medical history questionnaires mailed to living relatives and surviving spouses
| | Cancer site: colorectal | Format: NR | Unaffected relatives: Medical records
| | Setting: Hospital
Anton-Culver^3^ 1996 | Study design: Consecutive case series | Patients: Population based cancer patients derivd from a surveillance program of Orange county registry; complete family history data available for 252 of 359 patients | Method of collection: Telephone interview using structured family history questionnaire | Relatives characteristics: First degree relatives
USA | Criterion standard: Cancer registry (although author states that personal interview is the standard relative to registry) | Age: 30 to 80 years | Medium: Paper and electronic | Affected relatives: Cancer registry
| | Cancer site: Breast | Format: Interview (questions included types of cancer dates of diagnosis, birth and death of all informant family members) | Unaffected relatives: Cancer registry
| | Setting: Population based surveillance program in Orange county
Breuer^4^ 1993 | Study design: Non-comparative | Patients: Patients attending High Risk program (patients had positive history for breast cancer in relatives) | Method of collection: Self completed questionnaire administered to patients prior to their first breast examination | Relatives characteristics: First and second degree
US | Criterion standard: Relatives medical/hospital records | Age: Mean age 45 years | Medium: Paper | Affected relatives: Personal interview with relatives and relatives medical record
| | Cancer site: Breast | Format: Not reported but after collection, data presented in a flow chart | Unaffected relatives: NR
| | Setting: Specialty clinic for high risk patients
Eerola^5^ 2000 | Study design: Non-comparative | Patients: Cancer patients diagnosed before the age of 40 and those with bilateral disease | Method of collection: Mailed questionnaires and interview | Relatives characteristics: First through to fifth degree
Finland | Criterion standard: Hospital records of the patients and relatives reported having cancer | Age: 20 to 70 years | Medium: Paper | Families traced back as far as the first healthy parents of the oldest known breast or ovarian cancer generation
| | Cancer site: Breast | Format: Table | Affected relatives: Medical records, cancer registry and parish registry
| | Setting: University hospital | | Unaffected relatives: Medical records, cancer registry and parish registry
Gaff^6^ 2004 | Study design: Non-comparative | Patients: Men free from cancer with a history of two or more relatives with prostate cancer or one relative with a history of prostate cancer before the age of 55; patients recruited from a population based study on prostate cancer | Method of collection: Face to face interview and mailed survey | Relatives characteristics: First, second and third degree relatives and beyond if available
Australia | Criterion standard: Cancer registry | Age: Mean 58 years (range 39 to 87) | Medium: Paper | Affected relatives: Relatives medical records
| | Cancer site: Prostate | Format: Non-pedigree format | Unaffected relatives: NR
| | Setting: Patients home, community setting (mailed survey)
Geller^7^ 2001 | Study design: Cross-sectional | Patients: Random sample of patients undergoing mammography (from the Vermont Breast Cancer Surveillance System) where the patients had no personal history of breast cancer, and a negative mammography | Method of collection: Telephone interview | Relatives characteristics: First, second and third degree relatives
USA | Criterion standard: Medical records | Age: <65 years | Medium: NR | Affected relatives: Personal interview with relatives, cancer registry - Vermont Breast Cancer Surveillance System
| | Cancer site: Breast | Format: Pedigree | Unaffected relatives: Same as for affected relatives
| | Setting: Mammography center
Glanz^8^ 1999 | Study design: Case-control | Patients: Population based case control study; first degree relatives of colon cancer patients | Method of collection: Mailed survey | Relatives characteristics: First degree relatives
USA | Criterion standard: Hawaii Tumor Registry, Medical records (histology reports confirming the colorectal cancer diagnoses) | Age: < 60 years; mean age of relatives was 50 years (range 19 to 84 years) | Medium: Paper | Affected relatives: Mailed survey to relatives
| | Cancer site: Colorectal | Format: NR | Unaffected relatives: Mailed survey to relatives
| | Setting: Patients home, community setting
Katballe^9^ 2001 | Study design: Non-comparative | Patients: Cancer patients derived from a prospective population based study | Method of collection: Interview by surgeon | Relatives characteristics: First and second degree relatives
Denmark | Criterion standard: Medical file or autopsy reports; Danish Cancer Registry; death certificates | Age: NR | Medium: Paper | Affected relatives: Relatives medical record; cancer registry; death certificate
| | Cancer site: Colorectal | Format: Pedigree | Unaffected relatives: NR
| | Setting: Specialty surgical clinic
Kerber^10^ 1997 | Study design: Case control | Patients: General population and from primary care setting | Method of collection: Face to face interview and computer assisted | Relatives characteristics: First degree relatives
USA | Criterion standard: Utah Population Database cancer registry | Age: 30 to 79 years | Medium: Electronic | Affected relatives: Utah Cancer registry
| | Cancer site: Breast, ovarian, prostate, colorectal | Format: NR | Utah Population Database
| | Setting: Patients home in a community setting | | Unaffected relatives: Utah Population Database
King^11^ 2002 | Study design: Non-comparative | Patients: Cancer patients | Method of collection: Face to face interview: type of collection not specified | Relatives characteristics: First degree relatives
USA | Criterion standard: Medical records and death certificates | Age: NR | Medium: Paper | Affected relatives: Relatives medical record
| | Cancer site: Prostate | Format: NR | Unaffected relatives: NR
| | Setting: Prostate clinic
Kupfer^12^ 2006 | Study design: Non-comparative | Patients: Patients at high risk for colorectal cancer | Method of collection: Telephone interview | Relatives characteristics: First degree relatives
USA | Criterion standard: Genetic counselor interview; pathology and operative records hospital admission and discharge summaries, death certificates and autopsy reports | Age: NR | Medium: NR | Affected relatives: Relatives medical record; pathology and operative reports,hospital admissions and discharge summaries; death certificate, autopsy reports
| | Cancer site: Colorectal | Format: Pedigree | Unaffected relatives: NR
| | Setting: Patients home/community setting, and at cancer clinic
Mitchell^13^ 2004 | Study design: Case control | Patients: Controls, general population and spouses of cases controls | Method of collection: Face to face interview conducted by genetics nurse | Relatives characteristics: First and second degree relatives
UK | Criterion standard: Cancer registry | Cancer patients: colorectal cancer cases | Medium: Paper | Affected relatives: Scottish Cancer Registry
| | Age: Mean age 64 years | Format: Pedigree | Unaffected relatives: Scottish Cancer Registry
| | Cancer site: Colorectal
| | Setting: Regional hospitals
Parent^14^ 1995 | Study design: Case control | Patients: Cases: French Canadian women recently diagnosed with cancer | Method of collection: Face to face interview | Relatives characteristics: First degree relatives
Parent^15^ 1997 | Criterion standard: Hospital records | Controls: General population | Medium: NR | Affected relatives: Relatives medical record
Canada | | Age: Mean age 59 years, (range 30 to 79 years) | Format: NR | Unaffected relatives: NR
| | Cancer site: Breast cancer
| | Setting: Patient's home, community setting
Schneider^16^ 2004 | Study design: Prospective cohort | Patients: First degree relatives of a Li-Fraumeni Syndrome cancer patient or an hereditaty breast ovarian cancer syndrome patient | Method of collection: Self completed survey | Relatives characteristics: First and second degree relatives
USA | Criterion standard: Medical records or death certificates | Age: >40 | Medium: Paper | Affected relatives: Relatives medical record, death certificate
| | Cancer site: Breast and ovarian | Format: Pedigree | Unaffected relatives: NR
| | Setting: NR
Sijmons^17^ 2000 | Study design: Non-comparative | Patients: Referred to genetic counseling clinic with and without cancer | Method of collection: Paper and interview | Relatives characteristics: First to fourth degree relatives
Netherlands | Criterion standard: Geneticist interview | Age: NR | Medium: Paper | Affected relatives: Medical records
| | Cancer site: Breast, ovarian, colorectal | Format: Pedigree | Unaffected relatives: NR
| | Setting: Patients home and genetic clinic
Theis^18^ 1994 | Study design: Non-comparative | Patients: Cancer patients | Method of collection: Face to face interview and self completed survey (mail) | Relatives characteristics: First and second degree relatives
Canada | Criterion standard: Relatives self report, medical records and Ontario Cancer Registry | Age: Range 31 to 70 years | Medium: Paper | Affected relatives: Personal interview with relatives
| | Cancer site: Breast, ovarian, prostate and colorectal | Format: NR | Unaffected relatives: A random sample of 100 first-degree relatives reported as unaffected by cancer submitted to the Ontario Cancer Registry in order to estimate under-reporting
| | Setting: Patients home, community and clinical
Weinrich^19^ 2002 | Study design: Non-comparative | Patients: Patients from a cancer registry and the African American Hereditary Cancer Study | Method of collection: Face to face interview first time | Relatives characteristics: First, second and third degree relatives and beyond
USA | Criterion standard: Hospital records | Age: Range 40 to70 years, mean age 50.4 years (SD=7.6) | Telephone interview done one year later | Affected relatives: Relatives medical record
| | Cancer site: Prostate | Medium: NR | Unaffected relatives: NR
| | Setting: Patient's home, community setting | Format: One Question “Have any of your men blood relatives ever had prostate cancer?”
Ziogas^20^ 2003 | Study design: Non-comparative | Patients: Cancer patients recruited from population based and clinic based family registries of breast, ovarian and colorectal cancer | Method of collection: Telephone interview | Relatives characteristics: First degree, second degree, third degree relatives and beyond
USA | Criterion standard: Pathology reports, tumor tissue samples or clinical records; relatives self-reports; death certificates | Age: NR | Medium: Electronic (interviewers entered data into Genetics Registry In System (GRIS)) | Affected relatives: Personal interview with relatives
| | Cancer site: Breast, ovarian, prostate, colorectal | Format: Pedigree produced from GRIS | Self completed survey, medical records, death certificate
| | Setting: Patients home, community setting | | Unaffected relatives: Personal interview with relatives
| | | | Self completed survey, medical records, death certificate

Abbreviations: GRIS=Genetics Registry in System; NR=not reported; SD=standard deviation

Table 2a Eligible studies evaluating family history tools applicable to primary care (18 tools from 22 publications)

Author, Year, Country | Study Population, Setting, Design | Tool Purpose, Data Collection Strategy and Format | Tool Structure: Informants, General Strategy | Tool Structure: Relatives | Tool Evaluation: Details | Tool Evaluation: Outcomes
Acheson^1^ 2006 | Participants: Patients attending genetics clinic, mean age 40 yrs | Tool: Genetic Risk Easy Assessment Tool (GREAT) | PMH: Risk factors for cancer | Side of family identified: Both | FH comparator Genetics interview | Tool vs comparator:
USA | Setting: Cancer genetics clinics | User: Patient | Strategy: General enquiry about 1DR, 2DR and first cousins | Relatives identified: 1DR, 2DR, 1st cousin | Sample size for analysis: n=120 | 1 Mean % per family of all members recognized; a 1DR - 98.5 v 97.3 (p > 0.05); b 2DR - 93.9 v 74.3 (p < 0.001);; c First cousin - 94.5 v 48.6 (p > 0.001); 2 Agreement on risk categories; a kappa=0.7; b correlation= 0.77; 3 Test-retest reliability; a 1DR 97%; b 2DR 93%; c cancer 98%
| Cancer type: 24 types of cancer excluding non-melanoma skin cancer | Medium: Automated telephone interview | Details of cancer in affected relatives | Information on affected relatives: Primary site of cancer, age of diagnosis, cause of death, age of death | Sample size calculation for FH outcomes: No
| Tool implementation: Mixed proactive and reactive | Output format: Pedigree | Information from more distant relatives only if they had cancer | Information on unaffected relatives: Age at death, exact relationship to informant
| Design: Non-controlled comparator study | Integrated with e-record: No
Benjamin^22^ 2003 | Participants: Patients attending joint surgical/genetics breast screening clinic, median age 38 yrs | Tool: Family history questionnaire | PMH: NR | Side of family identified: Both | FH comparator: Genetics interview | Tool vs comparator:
UK | Setting: Specialist genetic clinic | User: Patient | Strategy: Direct questions for details of relatives with breast cancer; details of cancers; number of relatives with ovarian and colorectal cancers; note of relatives with sarcoma, leukemia or brain tumor | Relatives identified: 1DR, 2DR, 3DR | Sample size for analysis: n=152 | 1 Sensitivity = 95% (95% CI 89 to 99%); 2 Specificity = 96% (95% CI 79 to 100%)
| Cancer type: Breast | Medium: Paper | | Information on affected relatives: Age, diagnosis and site, risk of developing breast cancer | Sample size calculation for FH outcomes: No
| Design: Uncontrolled prospective cohort | Output format: NR | | Information on unaffected relatives: NR
| Tool implementation: Reactive | Integrated with e-record: No
Braithwaite^23^ 2005 | Participants: Womenwith family history of breast cancer, age ≥18 yrs | Tool: Genetic Risk Assessment in the Clinical Environment (GRACE) | PMH: Relevant past medical history | Side of family identified: Both | FH comparator: Genetics interview | NA
UK | Setting: Genetics clinic | User: Patient | Strategy: Not clear | Relatives identified: 1DR, 2DR | Sample size for analysis: NA
| Cancer type: Breast | Medium: Electronic | | Information on affected relatives: Site of cancer | Sample size calculation for FH outcomes: NA
| Tool implementation: Reactive | Output format: Pedigree | | Information on unaffected relatives: NR
| Design: Randomized controlled trial | Integrated with e-record: NR
Colombet^24,25^ 2003 | Participants: Family physicians | Tool: Personalized Estimate of Risk (EsPeR) | PMH: NR | Side of family identified: Both | FH comparator: None | NA
France | Setting: Research | User: Professional | Strategy: ‘Dynamic data input’ capturing family history | Relatives identified: NR | Sample size for analysis: NA
| Cancer type: Breast, colorectal, prostate | Medium: Electronic | | Information on affected relatives: Site of cancer | Sample size calculation for FH outcomes: NA
| Tool implementation: Reactive | Output format: Pedigree | | Information on unaffected relatives: NR
| Design: Formative evaluation (qualitative) | Integrated with e-record: NR
De Bock^26^ 1997 | Participants: Family practice patients, 25 to 50 yrs | Tool: Structured interview | PMH: NR | Side of family identified: Both | FH comparator: None | NA
Netherlands | Setting: Family practice | User: Professional | Strategy: Not clear | Relatives identified: 1DR, 2DR | Sample size for analysis: NA
| Cancer type: Breast | Medium: Structured interview | | Information on affected relatives: Exact relationship to informant; age of diagnosis; cause of death; age of death; site of cancer | Sample size calculation for FH outcomes: NA
| Tool implementation: Reactive | Output format: NR | | Information on unaffected relatives: NR
| Design: Cross-sectional survey | Integrated with e-record: No
Emery*^21^ 2000 | Participants: Family physicians | Tool: Risk Assessment in Genetics (RAGS) (prototype) | PMH: Reported | Side of family identified: Both | From Emery^21^ 2000 FH comparator: | Tool vs comparator:
Emery^27^ 1999 | Setting: Family practice | Genetic Risk Assessment in an Intranet and Decision Support (GRAIDS) | Strategy: Not clear | Relatives identified: NR, from presented pedigrees, likely 1DR, 2DR | 1 Current practice (pen & paper); 2 Modified current practice (Cyrillic pedigree tool) | 1 Median # correct pedigrees. RAGS - 5.06/6 Cyrillic - 3.5/6 Pen & paper - 2.0/6 p<0.0001; 2 Preferred method RAGS - 75% Cyrillic - 8% Pen & paper - 17%; 3 Ease of use RAGS - 86% Cyrillic - 8% Pen & paper - 6%
Emery ^28^ 2005 | Cancer type: Breast colorectal | User: Professional | | Information on affected relatives: Exact relationship to informant, age of diagnosis, age of death | Sample size for analysis: completing pedigrees for 6 simulated patients per arm n=36
Emery^29^ 2007 | Tool implementation: Reactive | Medium: Electronic | | Information on unaffected relatives: NR | Sample size calculation for FH outcomes: No
UK | Design: Randomized cross-over trial with simulated cases^21^ | Output format: Pedigree
| | Integrated with e-record: RAGS - no
| | GRAIDS - potentially, software connected to NHS intranet
Fisher^30^ 2003 | Participants: Repeat screening mammogram | Tool: Family history questionnaire | PMH: NR | Side of family identified: Both | FH comparator: Genetic interview | Tool vs comparator:
Australia | Setting: Breast screening clinic | User: Patient | Strategy: Direct questions on breast cancer and age of diagnosis in specific relatives (1DR, DR) - linked with guideline recommendation | Relatives identified: 1DR, 2DR | Sample size for analysis: n=89 | 1 Agreement on risk categorization on basis of FH data (population v elevated) - 100% agreement; 2 Errors in completing FHQ risk category not identified - 5%
| Cancer type: Breast, Ovarian | Medium: Paper | | Information on affected relatives: Relationship to informant, age of exact diagnosis | Sample size calculation for FH outcomes: No
| Tool implementation: Reactive | Output format: NR | | Information on unaffected relatives: NR
| Design: Cross-sectional survey | Integrated with e-record: No
Frezzo^31^ 2003 | Participants: Patients attending internal medicine clinic, age range 21 to 76 years | Tool: Family history questionnaire | PMH: NR | Side of family identified: NR | FH comparator: Patient charts - parallel tool group and genetics interview group validated against medical records | Tool vs comparator:
USA | Setting: Clinic | User: Patient | Strategy: Not clear - focus on specific conditions | Relatives identified: NR | Sample size for analysis: | (parallel groups)
| Cancer type: Breast, Colorectal, ovarian | Medium: Paper | | Information on affected relatives: NR | Tool group n=39 | 1 # at risk on basis of FH data,; a breast/ovarian cancer tool - 2/39, chart 0/39 interview - 5/39, chart 2/39; b colon cancer tool - 3/39, chart - 1/39 interview - 4/39, chart 2/39
| Tool implementation: Proactive | Output format: NR | | Information on unaffected relatives: NR | Interview group n=39
| Design: Quasi-randomized controlled trial | Integrated with e-record: No | | | Sample size calculation for FH outcomes: No
Grover^32^ 2004 | Participants: Cancer patients, median 58 yrs | Tool: Family history questionnaire | PMH: Reported | Side of family identified: Both | FH comparator: Patient charts | Tool vs comparator:
USA | Setting: Gastrointestinal cancer clinic | User: Patient | Strategy: Not clear | Relatives identified: 1DR, 2DR, 3DR | Sample size for analysis: n=387 | 1 Concordance of relatives' diagnosis and type of cancer 258/387 = 67%; 2 Of 311 with 1DR or 2DR with cancer (either method) - 184/311 = 59% concordance; 3 Of 127 where data discordant, 37/127 charts did not record or recorded a negative FH where tool had reported positive FH; 4 834 cancers reported in FHxT, 265 (32%) NR in charts
| Cancer type: Colorectal | Medium: Paper | | Information on affected relatives: Age of diagnosis; site of cancer | Sample size calculation for FH outcomes: No
| Tool implementation: Reactive | Output format: NR | | Information on unaffected relatives: NR
| Design: Cohort study | Integrated with e-record: No
House^33^ 1999 | Participants: All patients on a single GP list, mean 44 yrs | Tool: Family history questionnaire | PMH: Colorectal polyp or cancer, radiotherapy or abdominal operation | Side of family identified: NR | FH comparator: None | NA
UK | Setting: Family practice | User: Patient | Strategy: Direct questions about PMH or FH of 1DRs with colorectal cancer or polyp; if positive FH it specifies details on affected 1DRs and FH for other specified cancers | Relatives identified: 1DR | Sample size for analysis: NA
| Cancer type: Colorectal | Medium: Paper | | Information on affected relatives: Exact relationship to informant; age of diagnosis; cause of death; age of death; exact diagnosis; site of cancer | Sample size calculation for FH outcomes: NA
| Tool implementation: Proactive | Output format: Tabular | | Information on unaffected relatives: NR
| Design: Cross-sectional survey | Integrated with e-record: No
Hughes^34^ 2003 | Participants: Patients in an internal medicine practice, age 21–80 yrs | Tool: Family history questionnaire | PMH: Breast/ovarian cancer, ethnicity | Side of family identified: Both | FH comparator: None | NA
USA | Setting: Internal medicine | User: Patient | Strategy: Not clear; set of specific questions and tick boxes | Relatives identified: 1DR, 2DR | Sample size for analysis: NA
| Cancer type: Breast, ovarian | Medium: Paper | | Information on affected relatives: Exact relationship to informant; age of diagnosis; exact diagnosis | Sample size calculation for FH outcomes: NA
| Tool implementation: Proactive | Output format: NR | | Information on unaffected relatives: Not clear
| Design: Cross-sectional survey | Integrated with e-record: No
Hurt^35^ 2001 | Participants: Female relatives of cancer patients, mean age 41yrs | Tool: Family history questionnaire | PMH: Breast cancer risk factors, ethnicity | Side of family identified: NR | FH comparator: None | NA
US | Setting: Comprehensive cancer centre | User: Patient | Strategy: Not clear | Relatives identified: 1DR, 2DR | Sample size for analysis: NA
| Cancer type: Breast | Medium: Paper | | Information on affected relatives: Exact relationship to informant; age of diagnosis; age of death; exact diagnosis | Sample size calculation for FH outcomes: NA
| Tool implementation: Proactive | Output format: NR | | Information on unaffected relatives: NR
| Design: Cohort study | Integrated with e-record: No
Kelly^36^ 2007 | Participants: Cancer patients, mean age 57.6 yrs | Tool: Family history questionnaire, based on Stemmerman structured interview | PMH: NR | Side of family identified: Both | FH comparator: Genetics interview | Tool vs comparator:
USA | Setting: Ambulatory gastrointestinal oncology clinic | User: Patient | Strategy: Direct questions on affected relatives | Relatives identified: 1DR | Sample size for analysis: n=96 | No discrepant data between methods on whether or not a relative had cancer
| Cancer type: Any type | Medium: Paper | | Information on affected relatives: Exact relationship to informant, age of diagnosis, site of cancer | Sample size calculation for FH outcomes: With 53 participants, 80% power to detect a difference in marginal proportions in the amount of unspecified data between the two methods of 0.14 at α=0.05 | a Missing data age - 5/53 9.4%); - diagnosis - 6/53 (11.3%); - age of diagnosis - 7/53 (13.2%); b Unspecified data; - age - 2/53 (3.8%); - diagnosis - 2/53 (3.8%); - age of diagnosis - 5/53 (9.4%)
| Tool implementation: Proactive | Output format: NR | | Information on unaffected relatives: NA
| Design: Randomized controlled crossover trial | Integrated with e-record: No
Murff^37^ 2007 | Participants: Internal medicine patients, mean age 38.9 yrs | Tool: Family history questionnaire | PMH: Personal medical history | Side of family identified: Both | FH comparator: Patient charts | Tool vs comparator:
USA | Setting: Internal medicine | User: Patient | Strategy: Identification of specified relatives, inserted into table where diagnoses and details entered | Relatives identified: 1DR, 2DR | Sample size for analysis: n=541 | 1 # 1DR relatives reported to have cancer; a colorectal = 19 vs 11; b breast = 64 vs 51; c ovarian = 11 vs 6; 2 # 2DR relatives reported to have cancer; a colorectal = 79 vs 31; b breast = 184 vs 52; c ovarian = 26 vs 5
| Cancer type: Breast, ovarian, colorectal | Medium: Paper | | Information on affected relatives: Relationship to informant, age of diagnosis, site of cancer | Sample size calculation for FH outcomes: No
| Tool implementation: Proactive | Output format: Table | | Information on unaffected relatives: NR
| Design: Cross-sectional survey | Integrated with e-record: Yes
Schroy^38^ 2005 | Participants: Internal medicine residents | Tool: PDA program | PMH: NR | Side of family identified: NR | FH comparator: Medical charts | Tool group vs control group
US | Setting: Internal medicine clinic | User: Professional | Strategy: Prompts for information on affected relatives | Relatives identified: NR | Sample size for analysis: Tool group - residents n=33, patients n=57 | 1 % patients report physician asked about family history of colorectal cancer: Tool group - 33% Control group - 25%, p=0.30,; 2 % patients report physician asked about family history of colorectal adenomas: Tool group - 25% Control group - 24%, p=0.89
| Cancer type: Colorectal | Medium: Electronic | | Information on affected relatives: Age of diagnosis. | Control group - residents n=48, patients n=69
| Tool implementation: Proactive | Output format: NR | | Information on unaffected relatives: NR | Sample size calculation for FH outcomes: No
| Design: Cluster randomized trial | Integrated with e-record: NR
Sweet^39^ 2002 | Participants: Patients attending oncology clinic | Tool: Jameslink | PMH: PMH of cancer and ethnicity | Side of family identified: Both | FH comparator: Patient charts | Tool vs comparator:
USA | Setting: Cancer centre clinic | User: Patient | Strategy: Not clear | Relatives identified: 1DR, 2DR, some 3DR | Sample size for analysis: n=362 | 1 Of 362 patients whose family histories captured by tool, only 308 (85%) had some FH recorded in medical records; 2 Discrepancies were noted between family histories captured by tool and those recorded in medical records
| Cancer type: Breast, ovarian, prostate, colorectal | Medium: Electronic | | Information on affected relatives: Age of diagnosis; exact diagnosis. | Sample size calculation for FH outcomes: No
| Tool implementation: Mixedproactive and reactive | Output format: NR | | Information on unaffected relatives: NR
| Design: Cross-sectional survey | Integrated with e-record: NR
Yang^40^ 1998 | Participants: Women in an ongoing cancer prevention prospective mortality study, median age in 1982 56 yrs | Tool: Family history questions embedded in health questionnaire | PMH: Recorded as part of main questionnaire | Side of family identified: NR | FH comparator: None | NA
USA | Setting: Epidemiological cohort study | User: Patient | Strategy: Direct questions on parents, siblings, details of cancers in relatives | Relatives identified: NR | Sample size for analysis: NA
| Cancer type: Breast | Medium: Paper | | Information on affected relatives: relationship to informant, age of diagnosis, age of death | Sample size calculation for FH outcomes: NA
| Tool implementation: NA | Output format: NR | | Information on unaffected relatives: NR
| Design: Cross-sectional data from cohort study | Integrated with e-record: NR

* Data relating to performance as a FHxT reported here pertain only to the RAGS prototype tool ^21^. For performance of GRAIDS as a RAT, please see Evidence Table Q3

Abbreviations: CI = confidence interval; DR = degree relative; FH = family history; FHxT = Family History Tool; GP = general practitioner; NR = not reported; PMH = past medical history; RAT = risk assessment tool; vs = versus; yrs = years

Table 2b Eligible studies using family history tools but with insufficient information or tools not applicable to primary care

Author, Year, Country | Study population, setting, design | Purpose, data collection strategy and tool format | Tool structure: Participants + | Tool structure: Details on Relatives † | Tool evaluation: Comparison* | Tool evaluation: other measures ˆ
Aitken^2^ 1995 | Patients: Patients referred to hospital | Purpose: Clinical use; proactive | Age of Participants: NR | Relatives' Cancers and other conditions: Colorectal and any cancers or bowel polyp or obstruction | Tools compared: Family and personal medical history questionnaire was mailed to the cases and controls, compared to relatives medical records & death certificates | Metric used to evaluate the adequacy of the tool: Accuracy of FH:
Australia | Practitioners: Questionnaire was self-administered by patients | Method used to collect FH: Self-completed mail survey | Details on Relatives: | Information on affected relatives: Determine the age of diagnosis, cause and of death | # of participants recruited in each group: n=419 patients | Sensitivity (#, %): Overall: 0.84 (95% CI 0.77 – 0.88); Cases: 0.87; Controls: 0.82, Specificity (#,%): Overall: 0.97 (95% CI 0.95 – 0.98); Cases: 0.97; Controls: 0.97, % overall agreement of FH (Table 1)
Study purpose: To assess the validity of self-reported family histories of colorectal cancer patients by comparing patients' reports with their first degree relatives' medical records | Setting where developed: Colonoscopy department from a hospital | Format: NR | Side of family identified: Mother's side relatives; Father's side relatives | Information on unaffected relatives: NR | # of participants in analysis: n=419 patients | Other outcomes measured: NR
| Applicability: Reviewed FHxT; not applicable to primary care | Medium: Paper | Participant PMH: NR | | # of first degree relatives: n=618 | Follow up: Validation study, no clinical use
| Setting where used: Community setting | Integrated with e-record: N/A (validation study) | Relatives identified: 1DR | | # of second degree relatives: NR
| Cancer type: Colorectal | | Strategy for FH enquiry: General enquiry about 1DR relative's age and age of death, specific enquiry about condition
| Study design: Cohort study (prospective)
Andrieu^41^ 2004 | Patients: Selected primary care/ community-based population: Patients from a population cancer registry contacted via GP | Purpose: Clinical use; proactive | Age of participants: NR | Relatives' Cancers and other conditions: | Tools compared: Family history questionnaire | Metric used to evaluate the adequacy of the tool: % Confirmed diagnosis (Table 2)
France | Practitioners: Trained interviewer | Method used to collect FH: Face to face personal interview using structured FHQ | Details on Relatives: | Colorectal (also site specified), | Compared to details on relatives in cancer registry & medical records | Other outcomes measured: Familial risk of developing CRC: 1.54 (95% CI 1.26–1.86), for first degree relatives RR 1.71 (95% CI 1.35–2.13) and for second degree relatives (RR 1.22 (95% CI 0.82–1.76)
Study purpose: To estimate the familial risk of colorectal cancer (CRC) and other cancers and to examine how these risks vary according to tumor site. | Setting where developed: Research | Format: NR | Side of family identified: NR | 21 other cancers documented: uterus-SAI, ovaries, breast, prostate, testes, stomach, pancreas, urinary bladder, kidney, thyroid, leukemia, melanoma | # of participants recruited in each group: n=767
| Applicability: FHxT not available for review | Medium: NR | Participant PMH: NR | Information on affected relatives: Identify exact relationship to informant, determine the age of diagnosis, determine the cause of death, determine the age of death, determine the site of cancer | # of participants in analysis: n=766 (761 independent families)
| Setting where used: Community setting | Integrated with e-record: No | Relatives identified: 1DR; 2DR | Information on unaffected relatives: NR | # of first degree relatives: Group 1: n=6160
| Cancer type: Colorectal | | Strategy for FH enquiry: | | # of second degree relatives: n=4352
| Study design: Other | | General enquiry about all 1DR and 2DR - DOB and age of death
| | | Specific enquiry of DQ each relatives medical history of cancer, age and place of diagnosis
Anton-Culver^3^ 1996 | Patients: Selected primary care /community-based population: Patients from a cancer registry | Purpose: research; proactive | Age of participants: Patients: 30–80 years or older | Relatives' Cancers and other conditions: Breast cancer | Tools compared: | Metric used to evaluate the adequacy of the tool: Sensitivity (#, %): 92% mothers and 88% for sister informants, Specificity (#,%): 99%
USA | Practitioners Trained interviewers, (Background NR) | Method used to collect FH: Telephone interview | Details on Relatives: | Information on affected relatives: Identify exact relationship to informant, determine the age of diagnosis, determine the cause of death, determine the age of death, determine exact diagnosis | (1) Population based cancer registry; (2) personal interviews | Other outcomes measured: familial breast cancer phenotypes
Study purpose:; 1) To evaluate the validity of family history information on breast cancer in mother and sisters of breast cancer patients from a population-based cancer registry (CR); 2) To characterize a consecutive series of breast cancer patients on the basis of reported FH: sporadic, familial and potentially hereditary forms | Setting where developed: Research: cancer registry | (From original FH-T): using structured FHQ | Side of family identified: | Information on unaffected relatives: Identify exact relationship to informant, determine the age of the diagnosis, determine the cause of death, determine the age of death
| Applicability: Reviewed FHxT; not applicable to primary care | Format: NR; Table | Mother's side relatives: mothers and sisters | | # of participants recruited in each group:
| Setting where used: Patient's home/ Community setting: telephone interview | Medium: Paper and electronic | Participant PMH: NR | | Group 1: n=359
| Cancer type: Breast | Integrated with e-record: Yes | Relatives identified: 1DR | | Group 2: n=359
| Study design: Non-comparative study (case series) | | Strategy for FH enquiry: | | # of participants in analysis:
| | | General enquiry about “All relatives'” DOB & age of death. Specific enquiry: DQ each relatives medical history of cancer, age of diagnosis | | Group 1: n=359
| | | | | Group 2: n=359
| | | | | # of first degree relatives:
| | | | | Group 1: NR
| | | | | Group 2: NR
| | | | | # of second degree relatives:
| | | | | Group 1: NR
| | | | | Group 2: NR
Breuer^4^ 1993 | Patients: Patients who attended the Strang High Risk (for Breast Cancer) program | Purpose: research; proactive | Age of participants: Patients or informants: mean age 45 years | Relatives' Cancers and other conditions: Breast cancer | Tools compared: Group 1 patients report | Metric used to evaluate the adequacy of the tool: Wilcoxon's rank sums test and fisher's exact test
USA | Practitioners: NR | Method used to collect FH: Self-completed survey | Details on Relatives: | Information on affected relatives: Identify exact relationship to informant and determine the age of diagnosis; determine the cause of death; determine exact diagnosis; determine the site of cancer | Group 2 hospital records | Other outcomes measured: NR
Study purpose: To validate reports on bilaterality status in first-degree relatives of women with a strong family history of breast cancer. | Setting where developed: Specialist clinic | Format: Did not report the format of data collection. After collection data were presented in a flow chart | Side of family identified: | Information on unaffected relatives: NR | # of participants recruited in each group:
| Applicability: FHxT not available for review | Medium: Paper | Mother's side relatives: mothers and sisters | | Group 1: n=112
| Setting where used: Patient's home/Community setting | Integrated with e-record: No | Participant PMH: NR | | Group 2: n=112
| Cancer type: Breast | | Relatives identified: | | # of participants in analysis: group 1: n=94, group 2: n=94
| Study design: Non-comparative study (case series) | | First and second degree relatives | | # of first degree relatives: group 1: NR, group 2: NR
| | | | | # of second degree relatives: group 1: NR, group 2: NR
Bruner^42^ 1999 | Patients: First degree relatives of a cancer patient. | Purpose: clinical use; proactive | Age of participants: Patients or informants age 44 to 56 years | Relatives' Cancers and other conditions: Prostate cancer | Tools compared: | Metric used to evaluate the adequacy of the tool: NR
USA | Practitioners: health educator and genetic counselor for expanded FH. | Method used to collect FH: Face to face personal interview: with health educator and genetic counselor; self-completed survey: questionnaire, mail. | Details on Relatives: | Information on affected relatives: determine the age of diagnosis; determine the cause of death; determine the age of death; determine exact diagnosis; determine the site of cancer | # of participants recruited in each group: Cancer registry | Other outcomes measured: PSA levels of men tested. Risk of cancer in men screened
Study purpose: Describe a model that assesses the risk factors of prostate cancer | Setting where developed: Specialist genetic clinic | Format: It doesn't report the format of data collection; data are presented in a pedigree format once collected | Side of family identified: | Information on unaffected relatives: NR | # of participants in analysis: 101 men
| Applicability: FHxT not available for review | Medium: Paper | Mother's side relatives | | # of first degree relatives: NR
| Setting where used: Specialty clinic (Cancer Center) | Integrated with e-record: Yes | Father's side relatives | | # of second degree relatives: NR
| Cancer type: Prostate | | Participant PMH NR
| Study design: Cohort study (prospective) | | Relatives identified 1DR
Chalmers^43^ 2001 | Patients: Patients from a Primary Care Provider Setting; First degree relatives of a cancer patient. | Purpose: research; proactive | Age of participants: Patients or informants: 24 – 54 years; | Relatives' Cancers and other conditions: Breast cancer; Ovarian, endometrial, colorectal cancers or sarcoma. | Tools compared: 1: The Information and Support Needs Questionnaire. | Metric used to evaluate the adequacy of the tool: NR
UK | Practitioners: NR. | Method used to collect FH: Telephone interview; Self-completed survey (mail) | Relatives: 50 or older, | Information on affected relatives: identify exact relationship to informant; determine the age of diagnosis; determine exact diagnosis; determine the site of cancer. | # of participants recruited in each group: Group 1: 42. | Other outcomes measured: NR
Study purpose: To develop and pilot test a newly developed questionnaire that collects information and supports the needs of women with breast cancer | Setting where developed: Research: pilot test. | Format: NR | Details on Relatives: | Information on unaffected relatives: NR | # of participants in analysis: group 1: 39.
| Applicability: FHxT not available for review | Medium: paper and electronic | Side of family identified: | | # of first degree relatives: group 1: NR.
| Setting where used: Patient's home/Community setting | Integrated with e-record: No | Mother's side relatives | | # of second degree relatives: group 1: NR.
| Cancer type: Breast | | Father's side relatives
| Study design: Non-comparative study (case series) | | Participant PMH NR
| | | Relatives identified 1DR, 2DR
| | | Strategy for FH enquiry: NR
de Jong^44^ 2006 | Patients: General population Patients from a Primary Care Provider Setting | Purpose: Research, Proactive | Age of participants: Patients or informants 45–70 years | Relatives' Cancers and other conditions: Colorectal | Tools compared: One Family history questionnaire | Metric used to evaluate the adequacy of the tool: Survey data collected anonymously, data not verified
Netherlands | Practitioners: Family physician: subjects were invited to participate in the study on behalf of their general practitioner | Method used to collect FH: Mailed survey, anonymous questionnaire | relatives: < 50 and any age | Information on affected relatives: To identify exact relationship to informant determine the age of diagnosis determine the site of cancer | # of participants recruited in each group: 5072 eligible for the study | Other outcomes measured: NR
Study purpose: To assess the prevalence of a positive family history of colorectal cancer within a random cohort among the Dutch population | Setting where developed: Primary care | Format: Table | Details on Relatives: | Information on unaffected relatives: Number of brothers and sisters | # of participants in analysis: 3973 questionnaires were returned
| Applicability: FHxT not available for review | Medium: Paper | Side of family identified: Mother's side relatives Father's side relatives | | # of first degree relatives: N/A
| Setting where used: General population | Integrated with e-record: No | Participant PMH: NR | | # of second degree relatives: N/A
| Cancer type: None | | Relatives identified 1DR
| Study design: Prospective cohort | | Strategy for FH enquiry: Family history questionnaire
Eerola^5^ 2000 | Patients: Cancer patients | Purpose: Clinical use; proactive | Age of participants: Patients or informants less that 40 years; | Relatives' Cancers and other conditions: Breast and ovarian cancer | Tools compared:; 1 Young patients< 40,; 2 Bilateral patients,; 3 Unselected patients were administered a family history questionnaire (NR) | Metric used to evaluate the adequacy of the tool:
Finland | Practitioners: NR. | Method used to collect FH: Self-completed survey: Series 1&2 mailed | Relatives 20 to 70 years | Information on affected relatives: identify exact relationship to informant; determine the age of diagnosis; determine the cause of death; determine exact diagnosis | # of participants recruited in each group: 1570 (170+118+1282) | Validation method:
Study purpose:; 1) To evaluate the validity of the family history of breast cancer reported by patients; 2) To evaluate the number of families and individuals at risk and potentially benefiting from surveillance. | Setting where developed: Oncology specialist clinic | Format: Table | Details on Relatives: | Information on unaffected relatives: NR | # of participants in analysis: group 1: 170, group 2: 118, group 3: 100 families identified (272 relatives diagnosed Breast/Ovarian. | (1) Disease; - Hospital records; - Cancer registry Sensitivity ( %): 87%; (2) Genealogy; - Church parish registers; - Population register centre
| Applicability: FHxT not available for review | Medium: paper | Side of family identified: Not specified | | # of first degree relatives: group 1: NR, group 2: NR, group 3: NR. | Other outcomes measured:; 1 Family history of ovarian cancer (ovarian cancer) among breast cancer families,; 2 Incorrectly reported or unconfirmed cases,; 3 Potential female candidates for genetic counselling, diagnostic testing
| Setting where used: Patient's home/Community setting | Integrated with e-record: No | Participant PMH NR | | # of second degree relatives: group 1: NR, group 2: NR, group 3: NR.
| Cancer type: Breast | | Relatives identified First degree relatives 3rd degree relatives and beyond: grand aunts and uncles
| Study design: Non-comparative study (case series)
Fletcher, 2006^45^ | Patients: Patients from a primary care provider | Purpose: Research, Proactively | Age of Participants: 35 to 55 years | Relatives' Cancers and other conditions: Colorectal | Tools compared: Survey vs medical record | Metric used to evaluate accuracy:
USA | Practitioners: General internist and gastroenterologists | Method used to collect FH: Paper based-survey, medical records | Details on Relatives: | Information on affected relatives: To identify exact relationship to informant, determine the age of diagnosis, determine the site of cancer | # of participants recruited in each group: n=1870 patients who returned the survey | Sensitivity (#, %): 59%
Study purpose: To compare screening practices and beliefs in patients with and without clinically important family history | Setting where developed: Primary Care and in settings other than Primary Care | Format: Table | Side of family identified: Mother's side relatives Father's side relative | Information on unaffected relatives: N/A | # of participants in analysis: n=1854 patients who reported adequate FH | Specificity (#,%): 95%
| Applicability: FHxT not available for review | Medium: Paper | Participant PMH: NR | | # of first degree relatives: 1DR with onset age ≤60 years or 2 or more 1st degree relatives at any age= 53 (2.9%); 1st degree relative with onset at ≥60 years or 2 or more 2nd degree relatives=162 (8.7%) | Outcomes (other than accuracy):
| Setting where used: Specialist genetic clinic | Integrated with e-record: Yes | Relatives identified: All blood relatives who had been diagnosed with colorectal cancer | | # of second degree relatives: other family history of colorectal cancer= 140 (7.6%) | - Family history prevalence: 355 (19.1%) respondents reported family history of colorectal cancer; - Beliefs; - Identification of risk: 407 (39.1%, 95% CI 36.1%, 42%) out of 1041 respondents < 50 respondents that their clinician had asked for FH colorectal cancer; 72.2% (95% CI 70.0, 76.4) of respondents 50 years or older said they had been asked about FH.; - Appropriate screening; - Screening test preference
| Cancer type: Colorectal | | Strategy for FH enquiry: Survey (self-reported FH) and medical chart review
| Study design: Prospective cohort
Green, 2007^46^ | Patients: Cancer patients | Purpose: Research, proactively | Age of Participants: Patients or informants and relatives | Relatives' Cancers and other conditions: Colorectal | Tools compared: Ontario Familial Colorectal Cancer Registry (OFCCR); | Metric used to evaluate the adequacy of the tool: Confirmed diagnosis of family member through review of medical records when possible
Canada | Practitioners: Ontario and Newfoundland Cancer Registries | Method used to collect FH: Mail-in family history questionnaire | Details on Relatives: | Information on affected relatives: To identify exact relationship to informant, determine the age of diagnosis, determine the site of cancer | Newfoundland Colorectal Cancer Registry (NFCCR) | Outcomes(other than accuracy): Newfoundland rate of FDR affected with CRC is 1.5-fold higher than in Ontario (p<0.0001)
Study purpose: To evaluate the contribution of genetic and environmental factors to the incidence of colorectal cancer | Setting where developed: In settings other than primary care, but it is applicable to primary care | Format: Pedigree | Side of family identified: | Information on unaffected relatives: N/A | # of participants recruited in each group: n=730
| Applicability: FHxT not available for review | Medium: Paper | Mother's side relatives Father's side relative | | # of participants in analysis: n=702
| Setting where used: Patients' home/Community setting | Integrated with e-record: No | Participant PMH: NR | | # of first degree relatives: In Newfoundland 31% (n=220) and in Ontario 20.4% (n=764) of cases had at least 1 first degree relative affected with CRC
| Cancer type: Colorectal | | Relatives identified: FDR, SDR | | # of second degree relatives: N/A
| Study design & relevance Prospective cohort | | Strategy for FH enquiry: Mail-in family history questionnaire
Hlavaty^47^ 2005 | Patients: Cancer patients; 1DR of cancer patients. | Purpose: research use | Age of participants: Patients or informants: Mean age at diagnosis 65.9 +/-12.1; | Relatives' Cancers and other conditions: Hereditary non-polyposis colorectal cancer, stomach, uterus, lungs, pancreas, pharynx, breast, lymphoma, hepatocellular, prostate. | Tools compared: 1: Family history of Colorectal cancer questionnaire | Metric used to evaluate the adequacy of the tool: NR
Slovakia | Practitioners: None (questionnaire was self-administered by patient) | Method used to collect FH: Face to face personal interview, Self-completed mailed survey | Relatives: over 40 years or 10 years younger than the youngest case of CRC in the family | Information on affected relatives: determine the age of diagnosis; determine the site of cancer | # of participants recruited in each group: Group 1: 34 patients | Other outcomes measured:; 1 Presence of at least 1 first degree relative with CRC in the family history was noted in 12 patients (35.5%),; 2 Mean of first degree relatives with positive family history: 6.3 + - 3.4,; 3 Mean of first degree relatives with negative family history
Study purpose: To evaluate the interest of first degree relatives of colorectal cancer patients to participate in colonoscopy screening and to compare the findings to controls with a negative family history | Setting where developed: Research | Format: NR. | Details on Relatives: | Information on unaffected relatives: NR | # of participants in analysis: group 1: 34 patients
| Applicability: Reviewed FHxT; not applicable to primary care | Medium: Paper | Side of family identified: | | # of first degree relatives: group 1: 237
| Setting where used: Hospital Internal Medicine | Integrated with e-record: No | Mother's side relatives | | # of second degree relatives: NR
| Cancer type: Colorectal | | Father's side relatives
| Study design: Cohort study (prospective) | | Participant PMH NR
| | | Relatives identified First degree relatives
Katballe^9^ 2001 | Patients: Specialist secondary care/tertiary care population: Cancer patients | Purpose: Clinical use; reactive | Age of participants: NR | Relatives' Cancers and other conditions: Any cancers | Tools compared: questionnaire used by patient's surgeon compared to relatives medical records +/- autopsy report +/- cancer registry +/- death certificates | Metric used to evaluate the adequacy of the tool:
Denmark | Practitioners: General Internist: surgeon | Method used to collect FH: Interviewed by surgeon using structured FHQ (not clear if face to face or phone) | Details on Relatives: | Information on affected relatives: determine the age of diagnosis; determine the site of cancer determine the cause of death; determine the age of death; | # of participants recruited in each group: Group 1: n=1328 eligible patients. | Correct cancer reported in relatives: 1DR correct 68.4% 1DR increase to 81.7%
Study purpose: To evaluate the accuracy of family history of hereditary non-polyposis colorectal cancer (HNPCC). | Setting where developed: Surgeons interviewed the patients | Format: Pedigree | Side of family identified: | Information on unaffected relatives: NR | # of participants in analysis: Group 1: n=1200 completed the questionnaire, reported that their families belonged to Amsterdam ii categories 1, 2 or 3 and these families were subjects of this study | Other (specify): true-positive rate
| Applicability: FHxT not available for review | Medium: Paper | Mother's side relatives | Supplementary genealogical details on relatives recorded from church registers | # of first degree relatives: Group 1 a total of 167 informants reported colorectal cancer among 196 first-degree relatives | Other outcomes measured:
| Setting where used: Surgical clinic | Integrated with e-record: No | Father's side relatives | | # of second degree relatives: Group 1: second degree relatives were considered if the patients were diagnosed before the age of 50 years or if colorectal cancer was reported among first-degree relatives number is NR | Correct allocation into risk categories= meet Amsterdam I & II
| Cancer type: Colorectal | | Participant PMH: info on CRC | | | False + 21% (3/14)
| Study design: Non-comparative study (case series) | | Relatives identified: First degree relatives second degree relatives (2DR consider if patients were diagnosed before the age of 50 or if colorectal cancer was reported among first-degree relatives) | | | False - 32% (7/18)
| | | Strategy for FH enquiry: not clear (specific DQ)
Kerber^10^ 1997 | Patients: General population, patients from primary care | Purpose: research; proactive | Age of participants: Patients 30 to 79 years | Relatives' Cancers and other conditions: Any cancers: colorectal, ovarian, uterine, breast and prostate. | Tools compared:; 1 Computer-assisted in-person interviewing,; 2 Utah Population Database | Metric used to evaluate the adequacy of the tool: Sensitivity (#, %): Colorectal 73%, Uterine 30%, Ovarian 60%, breast 83%, prostate 70%
USA | Practitioners: NR | Method used to collect FH: Face to face (structured) personal interview | Details on Relatives: | Information on affected relatives: identify exact relationship to informant; determine the age of diagnosis; determine the cause of death; determine the age of death; determine exact diagnosis | # of participants recruited in each group: Group 1: 881, group 2: 331 | Other outcomes measured: 1: Risk of colon cancer associated with family histories of various cancers
Study purpose: To evaluate the sensitivity of patients' reports of familial cancer and to measure agreement between patients' reports and records in the Diet, Activity and Reproduction in Colon Cancer (DARCC) study | Setting where developed: | Format: NR | Side of family identified: NR | Information on unaffected relatives: NR | # of participants in analysis: group 1: 881, group 2: 331
| Research setting | Medium: On electronic medium | Participant PMH NR | | # of first degree relatives: group 1: 881, group 2: 331
| 1) Kaiser Permanente Medical Care Program Northern California;; 2) the Twin Cities metropolitan area; and; 3) an eight-county metropolitan area Salt Lake City, Utah, | Integrated with e-record: No | Relatives identified 1DR relatives | | # of second degree relatives: group 1: NR, group 2: NR
| Applicability: Reviewed FHxT; not applicable to primary care
| Setting where used:; 1) Kaiser Permanente Medical Care Program Northern California;; 2) the Twin Cities metropolitan area; and; 3) an eight-county metropolitan area surrounding Salt Lake City, Utah,
| Cancer type: Breast, ovarian, colorectal, prostate
| Study design: Cohort study (prospective)
King^11^ 2002 | Patients: Men with prostate cancer | Purpose: research use; reactive | Age of participants: NR | Relatives' Cancers and other conditions: Any cancers | Tools compared: Interview, compared to medical record, pathology report, death certificate | Metric used to evaluate the adequacy of the tool:
USA | Practitioners: trained interviewer | Method used to collect FH: personal structured interview: (Not clear if face to face or telephone interview) | Details on Relatives: | Information on affected relatives: age of relatives; determine the date of diagnosis; determine the cause of death; determine the date of death; determine the site of cancer; locality of Cancer Rx facilities, contact details | # of participants recruited in each group: Group 1: 442, group 2: 442 | % agreement between self-report & actual relatives medical history
Study purpose:; 1) To examine the accuracy of prostate cancer patients' reports on specific cancer types in their families;; 2) To report on the ability of investigators to document patients' report on their FH status | Setting where developed: Prostate Clinic | Format: NR | Side of family identified: | Information on unaffected relatives: age of relatives; cause of death | # of participants in analysis: group 1: 143, group 2: 249 | Vary by site:
| Applicability: FHxT not available for review | Medium: NR | Mother's side relatives | | # of first degree relatives: group 1: 263, group 2: 263 | Bladder/kidney (100% x/y)
| Setting where used: Prostate Clinic | Integrated with e-record: No | Father's side relatives | | # of second degree relatives: group 1: NR, group 2: NR | Prostate (80% x/y)
| Cancer type: Prostate | | Participant PMH NR | | | Ovarian (50% x/y)
| Study design: Non-comparative study (case series) | | Relatives identified First degree relatives (1DR) | | | 1DR accuracy 62–73% except brother 84%
| | | Strategy for FH enquiry: ask about all 1DR. If cancer identified in relatives, specific probes about detail | | | Other outcomes measured: NR
Parent^15^ 1997 | Patients: | Purpose: research; proactive | Age of participants: Patients: General population no older than 79 years; Mean age of women reporting positive family history of breast cancer was 59, ages ranged from 30–79. | Relatives' Cancers and other conditions: Breast cancer | Tools compared: Home FH interview compared to medical record (+/- path diagnosis) of 1DR +/- contact relatives | Metric used to evaluate the adequacy of the tool: NR
Parent^14,14^ 1995 | CONTROLS: Non-specialist secondary care/territory care population General population: women who had no history of breast cancer | Method used to collect FH: Face to face personal structured FH interview | Details on Relatives: Side of family identified: Not specified | Information on affected relatives: determine the age of diagnosis; determine the site of cancer, DOB, date of death | Number of participants recruited in each group: 843 women; 414 patients, 429 controls | Other outcomes measured: Accuracy data; 1: 68 cases and 37 controls reported a history of breast cancer in at least one first degree relative. 67 (91%) cases accurate 32 (97%) controls
Canada | CASES: Specialist secondary care/tertiary care population | Format: NR | Participant PMH NR | Information on unaffected relatives: NR | Number of participants in analysis: 68 women with breast cancer and 37 without
Study purpose: To evaluate the accuracy of affected and unaffected women's reports of breast cancer in first-degree relatives | Cancer patients: women diagnosed with cancer | Medium: NR | Relatives identified First degree relatives Other: they were asked if they has relatives affected in general | | Number of first degree relatives: 87, 38 by control reports of breast cancer in first-degree relatives
| Practitioners: NR | Integrated with e-record: No | Strategy for FH enquiry: Not clear | | Number of second degree relatives: NR
| Setting where developed: specialist clinic: Oncology Network
| Applicability: FHxT not available for review
| Setting where used: Hospital; Patients home/Community setting
| Cancer type: Breast
| Study design: Cohort study (prospective)
Quillin^48^ 2006 | Patients: Unselected primary care, community-based population patient's attending women's health clinic | Purpose: research; proactive | Age of participants: 40 years or older; largest proportion: 55.8% age 40–49. Relatives' age NR | Relatives' Cancers and other conditions: One syndrome cancer: focus of study on Breast Cancer, Any cancers identified | Tools compared: 1: Self administered paper questionnaire. | Metric used to evaluate the adequacy of the tool: NR
USA | Practitioners: None (self-administered by patient) | Method used to collect FH: Self-completed survey: Questionnaire was completed in the clinic | Details on Relatives: | Information on affected relatives: identify exact relationship to informant: determine the age of diagnosis: determine the cause of death: if died from cancer, determine exact diagnosis | # of participants recruited in each group: 899 | Other outcomes measured: 1: McNemar odds of reporting a maternal family history of breast cancer was 1.71 times greater than the odds of reporting paternal family history (p< 0.01, 95% CI 1.26 – 2.34). FH not validated
Study purpose: Test the hypothesis that women not pre-selected for familial risk report family history of breast cancer in fewer paternal than maternal relatives | Setting where developed: Primary care women's health clinic | Format: Tabular | Side of family identified: | Information on unaffected relatives: not collected | # of participants in analysis: as above
| Applicability: Reviewed FHxT; not applicable to primary care | Medium: paper | Mother's side relatives | | # of first degree relatives: NR
| Setting where used: Primary care women's health clinic | Integrated with e-record: No | Father's side relatives | | # of second degree relatives: NR
| Cancer type: Breast | | Participants PMH: Reported with details on ethnicity, breast cancer, previous genetic counseling | | # of relatives; 202
| Study design: Non-comparative study (case series) | | Relatives identified Any relative (excluded mothers with Breast cancer)
| | | Strategy for FH enquiry: DQ: list relatives with any form of cancer, with prompts for side of family, “kind of cancer”, age of diagnosis, and if died from cancer
Sijmons^17^ 2000 | Patients: Specialist secondary care/tertiary care population Patient referred to Genetic clinic with FH cancer | Purpose: Clinical use - reactive and proactive | Age of participants: Patients age NR | Relatives' Cancers and other conditions: Any cancers (exclude metastasis) | Tools compared: FHQ compared to medical record,(+/- path reports) | Metric used to evaluate the adequacy of the tool: Accuracy of Ca by site:
Netherlands | Practitioners: (self-administered by patient) Geneticist | Format: Pedigree | Relatives age NR | Information on affected relatives: DOB; date of death; determine the age of diagnosis; determine the cause of death; determine exact diagnosis; determine the site of cancer | # of participants recruited in each group: 129 | Br Ca (93%)
Study purpose: Examine the accuracy of the family history of cancer. | Setting where developed: Specialist genetic clinic | Medium: Paper | Details on Relatives: | Information on unaffected relatives: DOB; date of death | # of participants in analysis: 120 | CRC (89%)
| Applicability: Reviewed FHxT; not applicable to primary care | Integrated with e-record: No | Side of family identified: | | # of first degree relatives: group 1: NR, group 2: NR | OvCa (71%),
| Setting where used: Genetic counseling clinic | | Mother's side relatives | | # of second degree relatives: NR | Other outcomes measured: NR
| Cancer type: Breast, ovarian and colorectal | | Father's side relatives
| Study design: Non-comparative study (case series) | | Participant PMH NR
| | | Relatives identified First and second degree relatives Most third degree relatives
Skinner, 2005^49^ | Type of article Journal article reporting a primary study | Purpose: Clinical use, proactively | Age of Participants: Patients or informants. Relatives | Relatives' Cancers and other conditions: Breast, colorectal | Tools compared: CRIS (Cancer Risk Intake System) | Metric used to evaluate accuracy:
USA | Study design: Non-randomized Trial | Method used to collect FH: Pedigree | Details on Relatives: | Information on affected relatives: To identify exact relationship to informant, determine the age of diagnosis, determine the site of cancer | # of participants recruited in each group: 227 | - Cancer risk assessment: 83 (47%) had Gail-calculated breast cancer risk high enough to warrant receipt of tailored messages on tamoxifen; - Cancer risk assessment: 71 (33%) had breast, ovarian or colon cancer risk high enough to warrant receipt of tailored messages on genetic counseling; - Cancer risk assessment: 31 (14%) had colon cancer risk high enough to warrant surveillance via colonoscopy and were currently non-adherent
Study Purpose: To evaluate the impact of the computerized cancer risk intake system (CRIS) | Participants: Patients from a primary care provider, family physician and general internist | Format: Questionnaire. It displays messages for patients to discuss with clinicians | Side of family identified: Mother's side relatives Father's side relative | Information on unaffected relatives: N/A | # of participants in analysis: 215
| Provider: General internist | Medium: Computerized | Relatives identified: FDR, SDR | | # of first degree relatives: N/A
| Tool development: Primary care | Integrated with e-record: No | Strategy for FH enquiry: Computer-based questionnaire about FH | | # of second degree relatives: N/A
| Setting:
| Cancer type: Breast, colorectal
| Study design & relevance Prospective cohort
Theis^18^ 1994 | Patients: Selected Secondary/ tertiary care population: Cancer patients | Purpose: research: Reactive. | Age of participants: Patients: 31 to 70 years. | Relatives' Cancers and other conditions: Any cancers. | Tools compared: tool 1: questionnaire (FHQ), tool 2:followup Interview (GI),; compared to contact relatives +/- medic records +/- ca register +/- death certificates # of participants recruited in each group: 203. | Metric used to evaluate the adequacy of the tool:
Canada | Practitioners: | Method used to collect FH: Tool 1: Self-completed FHQ FH (mail) | Details on Relatives: | Information on affected relatives: identify exact relationship to informant; determine the cause of death; determine the date of death; determine the age of diagnosis; determine exact diagnosis; determine the site of cancer; details of any breast surgery | # of participants in analysis: 165. | Compare accuracy FHQ & GI
Study Purpose: To compare FH data of women with breast cancer obtained from a newly developed questionnaire with data obtained in a subsequent interview | Tool 1 self-administered by patient | Tool 2: follow-up Face to face personal GI | Side of family identified: Not specified | Information on unaffected relatives: identify exact relationship to informant; determine the cause of death; determine the date of death. | # of first degree relatives: 1,200 for both groups. | (1) Quantitative
| Tool 2 by interviewers in clinic setting | Format: Tool 1: Tabular | Participant PMH NR | | # of second degree relatives: 3, 456 for both groups. | First degree relatives (presence of cancer; site & age diagnosis) GI slightly better FHQ
| Setting where developed: Secondary care clinic | Medium: Tool 1: Paper medium: Questionnaire | Relatives identified First and second degree relatives. | | | Second degree relatives
| Applicability: FHxT not available for review | Integrated with e-record: No | Strategy for FH enquiry Not clear | | | GI better (age of diagnosis [11%]>presence of cancer [7%] > site diagnosis [5%])
| Setting where used: Secondary care clinic | | | | | Other outcomes measured: Accuracy of FH: age of diagnosis 1DR>2DR
| Cancer type: Breast/ovarian, prostate, colorectal
| Study design: Non-comparative study (case series)
Tischkowitz^50^ 2000 | Patients: cancer genetic clinic | Purpose: clinical use; reactive | Age of participants: Patients: NR; | Relatives' Cancers and other conditions: Breast and ovarian cancer. | Tools compared: 1: one tool - NR asking detailed family history extending to at least 3 generations | Metric used to evaluate the adequacy of the tool: NR
UK | Practitioners: Geneticist | Method used to collect FH: NR | relatives: younger than 50 years | Information on affected relatives: determine the age of diagnosis. | # of participants recruited in each group: Group 1: 200 women participating in the TRACE study. | Other outcomes measured: 1: Risk assessment as measured with 3 methods:; 1) CASH,; 2) Houlston/Murday and; 3) Qualitative see table 1 for results
Study purpose: To compare three methods used to estimate the risk for breast cancer in a group of high risk women | Setting where developed: Specialist genetic clinic | Format: Pedigree | Details on Relatives: | Information on unaffected relatives: Age of all unaffected female relatives was recorded. | # of participants in analysis: group 1: 200.
| Applicability: FHxT not available for review | Medium: NR | Side of family identified: | | # of first degree relatives: NR
| Setting where used: Genetic counselling clinic | Integrated with e-record: Yes | Mother's side relatives | | # of second degree relatives: NR
| Cancer type: Breast | | Father's side relatives
| Study design: Non-comparative study (case series/ reliability) | | Participant PMH NR
| | | Relatives identified First, second, third degree relatives and beyond
Weinrich^19^ 2002 | Patients: Selected primary care/community-based population men from a cancer registry (African American Hereditary Prostate Cancer study) | Purpose: research; reactive | Age of participants: Patients or informants: mean age 50.4 SD=7.6 | Relatives' Cancers and other conditions: prostate cancer. | Tools compared:; 1 question at time 1,; 2 question at time 2. | Metric used to evaluate the adequacy of the tool: NR
USA | Practitioners: | Method used to collect FH: DQ on Face to face personal interview: in-person interview first time, Identical Telephone interview: second interview one year later | Details on Relatives: | Information on affected relatives: determine exact diagnosis; determine the site of cancer | # of participants recruited in each group: 96 | Other outcomes measured: 1: change between time 1 and time 1 self-report (one year later) (Precision) 48 different response on 2nd enquiry 1 year later
Study purpose: To report on the stability of self-reported family history of prostate cancer over one-year time | NR: first interview | Format: Not clear | Side of family identified: | Information on unaffected relatives: NR | # of participants in analysis: 96
| Nursing student second interview | Medium: NR | Mother's side relatives | | # of first degree relatives: group 1: NR, group 2: NR.
| Setting where developed: Research | Integrated with e-record: No | Father's side relatives | | # of second degree relatives: group 1: NR, group 2: NR
| Applicability: FHxT not available for review | | Participant PMH NR
| Setting where used: Face to face interview at a community-based educational program on prostate cancer screening | | Relatives identified If positive family history for Prostate Cancer; identify First degree (Brother; Father; son) Second degree positive (Grand Parents; Grand Parents siblings)
| Cancer type: Prostate | | Strategy for FH enquiry: specific direct enquiry about FH Prostate cancer. If positive identify specific relatives
| Study design: Non-comparative study / reliability
Ziogas^20^ 2003 | Patients: Selected primary care/community-based population Cancer patients | Purpose: research; reactive | Age of participants: Informants Age is not specified although informants are presented subdivided in 5 age groups from <40 years to 70+ | Relatives' Cancers and other conditions: One syndrome cancer: focus on breast, ovarian, colon, any cancers | Tools compared:; 1 Telephone interview,; 2 Self report, pathology report, death certificate | Metric used to evaluate the adequacy of the tool: False positive rate and false negative rate
USA | Practitioners: Interviewers (not specified) | Method used to collect FH: Telephone interview | Details on Relatives: | Information on affected relatives: identify exact relationship to informant determine the age of diagnosis, determine the cause of and age of death | # of participants recruited in each group: n=1111 | Other outcomes measured: 1: CI, confidence interval; NPV, negative predictive value; PAC, probability of agreement of cancer; PANC, probability of agreement of no cancer
Study purpose:; 1) to evaluate the consistency of patient-reported information on cancer in their first-, second- and third-degree relatives; 2) To determine the positive and negative predictive values and probabilities of agreement between the patient-reported cancer status in relatives and the reference standard for various cancer sites; 3) to determine the effect of the characteristics of the patient's relatives on the probability of agreement between patient-reported information and reference standard | Setting where developed: Research | Format: Pedigree | Side of family identified: Mother's side relatives | Information on unaffected relatives: identify exact relationship to informant, determine the age of the diagnosis | # of participants in analysis: n=1111
| Applicability: Reviewed FHxT; not applicable to primary care | Medium: electronic medium: interviewers entered data into Genetics Registry In System (GRIS) | Participant PMH: NR | | # of first degree relatives: not clear
| Setting where used: Patient's home/Community setting | Integrated with e-record: Not clear | Relatives Age is not specified although informants are presented subdivided in 5 age groups from <50 years to 70+ | | # of second degree relatives: not clear
| Cancer type: Breast/ovarian and colorectal | | Participant's relevant past medical history: NR | | # of relatives: 3222
| Study design: Non-comparative study (case series) | | Relatives identified: 1DR, 2DR, 3DR
| | | Strategy for FH enquiry: Not clear

+ details collected on participants and relatives;

† extent of details collected on i) relatives' conditions ii) affected relatives iii) unaffected relatives;

* a) comparison with clinical genetics pedigree (i.e. gold standard) b) other tool;

ˆ other measures - accuracy, validity, reliability

Abbreviations: BE = best estimate; Br Ca= Breast Cancer; Ca=Cancer; CASH=Cancer and Steroid Hormone; CFHF= Comprehensive Family History Form CR = cancer registry; CRC=colorectal cancer; Cyr = cyrillic; DARCC= Diet, Activity and Reproduction in Colon Cancer; DOB=date of birth; DQ=direct question; DR=degree relative; EsPeR= Personalized Estimate of Risks; FCAT = familial cancer assessment tool; FH=family history; FHQ=family history questionnaire; FHxT = family history tool; GCI = genetic counselor interview; GI = genetic interview; GNI = genetic nurse interview; GP=general practitioner; GRACE = Genetic Risk Assessment in the Clinical Environment; GRAIDS = Genetic Risk Assessment in an Intranet and Decision Support; GRIS= Genetics Registry In System; HNPCC= Hereditary Non-polyposis Colorectal Cancer; IM=Internal Medicine; MR = Medical Record; NICE= National Institute for Clinical Excellence; NR = NR; Ov Ca= Ovarian Cancer; PAC= probability of agreement of cancer; PANC= probability of agreement of no cancer PC = primary care; PDA=Personal Digital Assistant; PMH=past medical history; PSA = Prostate-Specific Antigen; PSI = physician structured interview; RR = relative risk; RAGs = Risk Assessment in Genetics; TRACE=Trial of genetic assessment in breast cancer

Table 3 Study characteristics for studies evaluating risk assessment tools (RATS)

Author, Year, Country | Tool, Purpose, Content and Format of tool, Underlying Guidelines/Models | Study Population, Cancer Type, Clinical Setting, Applicability | Study Design, Comparison Group(s) or Interventions, Sample Size | Key Results Relating to Clinical Utility
Benjamin^22^ 2003 | Tool: Familial Cancer Assessment Tool (FCAT) | Study population: Patients referred to joint surgical/genetics family history breast screening clinic | Design: Tool development and description | Practice-related outcomes: Ease of completion rated by nurse interviewer on 1–10 scale (easy-difficult)
UK | Purpose: Stratify risk of familial breast cancer | Cancer type: Breast | Comparison groups:; 1 Text of GP letter; 2 Postal self-completion family history questionnaire alone; 3 Genetic interview (gold standard) | - 60/100 scales were rated 1–3
| Content: Directed family history questions based on guideline with suggested onward management | Setting: Specialist genetic clinic | Groups sample size for each group: n=152 | Other outcomes reported: Sensitivity, specificity, positive predictive value, negative predictive value; gold standard = genetic interview
| Format: Nurse-administered interview-based questionnaire, following patient completed advance family history questionnaire | Applicability: Potentially applicable to, but not developed or evaluated in, primary care setting
| Underlying guidelines: Eccles DM et al. J Med Genet 2000; 37: 203–9
Braithwaite^23^ 2005 | Tool: Genetic Risk Assessment in the Clinical Environment (GRACE) | Study population: Women with family history of breast cancer recruited from general population through advertisements | Design: Randomized controlled trial | Practice-related outcomes:
UK | Purpose: Cancer risk assessment and communication | Cancer type: Breast | Comparison group(s): Interview by clinical nurse specialist. | 1 Acceptability to patients (post-clinic); (a) Attitude to interventions - six attributes, 5-point scale; - 2/6 comparisons statistically significant, favored control arm; (b) Perceived benefits of interventions - seven attributes, 5-point Likert scale; - 7/7 comparisons statistically significant, favored control arm; (c) Perceptions of risk information - five attributes, 5-point Likert scale; - 5/5 comparisons statistically significant, favored control arm; (d) Satisfaction and risk communication preferences - single item, 4-point Likert scale; - 1/1 comparisons statistically significant, favored control arm; 2 Cognitive outcomes (all baseline, post-clinic, 3 months); (a) Comparative risk perception single item, 5-point scale; - No significant difference between GRACE and control arms; statistically significant time × treatment interaction indicated reduction in elevated risk perceptions in control arm compared to GRACE arm; (b) Risk accuracy - binary concordance between participant and guideline/clinical nurse specialist; - No significant improvements in accuracy of risk perception observed in GRACE and control arms. Baseline differences between arms; 3 Affective outcomes; (a) Hospital Anxiety and Depression Scale score (baseline, 3 months); - No significant difference between arms or between baseline and 3 months; (b) Current anxiety - Spielberger's State-Trait Anxiety Inventory (short form) (baseline, post-clinic, 3 months); - Statistically significant increase in scores baseline-3 months in both arms; statistically significant treatment effect, favored control; (c) Cancer worry (baseline, 3 months); - statistically significant decrease in cancer worry in both arms; no statistically significant difference between arms
| Content: Pedigree-based family history data collection with personalized risk report | Setting: Unspecified ‘clinical environment’ | Comparison and intervention arms returned self-completion postal family history questionnaire at baseline | Other outcomes reported: N/A
| Format: Patient-completed, computer-based questionnaire | Applicability: Potentially applicable to, but not tested in, primary care setting | Sample size: GRACE: n=38
| Underlying guidelines: Claus, EB et al. Am J Human Genetics 1991; 48( 2), 232–42 | | Control: n=38
| | | Power calculation: No
Colombet^24,25^ 2003 | Tool: EsPeR System | Study population: Physicians in individual practice, teaching, health centers | Design: Description of tool | Practice-related outcomes: N/A
France | Purpose: Health professional decision-support | Cancer type: Breast, prostate, colorectal | Comparison groups: N/A | Other outcomes measured: N/A
| Content: Family history collection, pedigree drawing, risk estimation based on published models, individualization of guidelines, printable summary of prevention messages for physicians and patients | Setting: Ambulatory care | Sample size: N/A
| Format: Physician-completed, interactive web-based system. | Applicability: Some formative, but not definitive, evaluation in primary care | Power calculation: N/A
| Underlying guidelines: Colombet I et al. Proc AMIA Symp 2002; 175–9; Gail model
Emery^27^ 1999 | Tool: Genetic Risk Assessment in an Intranet and Decision Support (GRAIDS), for which Risk Assessment in Genetics (RAGS) was the prototype | Patients: Family practice patients, family physicians | Design: Cluster randomized controlled trial with adaptive sub-group in intervention arm | Practice-related outcomes:
Emery^21^ 2000 | Purpose: Management of familial cancer in primary care | Cancer type: Breast, ovarian, colorectal | Comparison groups: | Practices
Emery^28^ 2005 | Content: Family history collection; pedigree drawing; patient-specific risk report; clinical practice guidelines/management advice; patient-specific explanations for the management advice | Setting: Family practice | 1 45 minute educational session plus mailing of regional guidelines; 2 Intervention as described, in fixed and adaptive sub-arms (adaptive received further input to promote greater software use) | 1 Appropriateness of referrals; a) consistency of family history reported in referral letter with regional guidelines; - Breast cancer - intervention 99/107, control 44/60, OR (95%CI) = 4.5 (1.6–13.1); - Bowel cancer - intervention 75/76, control 23/25, OR (95%CI) = 6.5 (0.5–83.7); - Combined - intervention 174/183, control - 67/85, OR(95%CI) = 5.2 (1.7–15.8), p=0.006; b) final expert risk assessment of referred patients; - Breast cancer - intervention 60/78, control 23/33, OR (95%CI) = 1.4 (0.6–3.5); - Bowel cancer - intervention 30/54, control 17/20, OR (95%CI) = 0.2 (0.1–0.8); - Combined - intervention 90/132, control - 40/53, OR(95%CI) = 0.7 (0.3–1.5), p=0.35; 2 Patients; a) Risk perception; Mean scores (SD) - intervention (referred) 4.99 (1.14), intervention (not referred) 4.25 (0.80) control 5.04 (0.88), Intervention (referred) v control, mean difference (95% CI)= -0.09 (0.34–0.51), NS; Intervention (not referred) v intervention (referred), mean difference (95%CI) = 0.74 (0.38–1.09), P<0.0001; b) Knowledge; Breast cancer:; Mean scores (SD) - intervention 5.77 (2.9), control 5.66 (2.78), mean difference (95% CI)= 0.11 (-1.05–1.27), NS; Colorectal cancer:; Mean scores (SD) - intervention 5.50 (2.46), control 4.86 (3.3), mean difference (95% CI)= 0.64 (-1.01–2.29), NS; c) Cancer worry; Mean scores (SD) - intervention (referred) 5.74 (3.04), intervention (not referred) 4.95 (2.99), control 7.18 (3.43); Intervention (referred) v control, mean difference (95% CI) = -1.44 (-2.64–0.23), P=0.02; Intervention (not referred) v intervention (referred), mean difference (95%CI) = 0.79 (-0.19–1.76), NS
Emery^29^ 2007 | Format: Web-based program designed to be used by a single lead physician in each practice. Preceded by an educational visit and a 2 hour training session; patients asked to complete family history questionnaire before attending practice | Applicability: Family practice | Sample size:; 1 Practices n=22; Referred patients n=84; 2 Practices n=23 (12 fixed, 11 adaptive); Referred patients n=162; Non-referred patients n=78
UK | Underlying guidelines: Claus, EB et al. Am J Human Genetics 1991; 48( 2), 232–42 | | Power calculation: 20 practices per arm required to demonstrate 15% difference between arms (β=0.2, α=0.05)
Fisher^30^ 2003 | Tool: Triage tool embedded in family history questionnaire | Study population: Patients having repeat mammograms | Design: Uncontrolled trial | Practice-related outcomes: # participants making errors affecting risk categorization - 29/559
Australia | Purpose: Permit women to assess their own risk of familial breast cancer | Cancer type: Breast | Comparison groups: None | Other outcomes measured: Concordance between questionnaire-based category (I, II or III, population, moderate, potentially high risk, according to cited guideline) and risk based on genetic counsellor telephone interview
| Content: Directed family history questions; risk triage (population or increased risk) and advice to see doctor if increased risk | Setting: Breast screening clinic | Sample size: Total n=559Validation study n=89
| Format: Patient-completion paper-based questionnaire | Applicability: Potentially applicable to primary care | Power calculation: NR
| Underlying guidelines: Advice about familial aspects of breast cancer and ovarian cancer: a guide for health professionals. Kings Cross, New South Wales: National Breast Cancer Centre, 2000
Gilpin^51^ 2000 | Tool: Family History Assessment Tool (FHAT) | Study population: Familial breast cancer registry plus patients referred to genetics clinic | Design: Tool development study | Practice-related outcomes: N/A
Canada | Purpose: Identify patients for referral | Cancer type: Breast, ovarian cancer | Comparison groups: N/A | Other outcomes measured: Sensitivity, specificity, positive predictive value, negative predictive value; gold standard unclear
| Content: Directed family history questions with points specified for each affected family member | Setting: Specialist genetic clinic | Sample size: N/A
| Format: Clinician-oriented, paper-based | Applicability: Designed to be applicable to, but not developed or evaluated in, primary care | Power calculation: N/A
| Underlying guidelines: Predictive scoring system, described in same paper
Gramling^52^ 2004 | Tool: ‘Brief tool’ for physicians | Study population: Internal medicine, family physicians | Design: Tool development study | Practice-related outcomes:; 1 Frequency of discussing inherited risk with patients with a family history of breast cancer (baseline, 3 months); - 5/7 reported decrease in frequency, 2/7 reported no change; 2 Subjective threshold for classifying a woman as ‘high risk’ (baseline, 3 months); - 6/7 reported increase in subjective threshold
USA | Purpose: Rapid assessment of family history | Cancer type: Breast | Comparison groups: None | Other outcomes measured: N/A
| Content: Risk stratification criteria; lifetime probability benchmark ranges; screening recommendations; genetics services contact numbers | Setting: Internal medicine, family practice | Sample size: n=7
| Format: Coat pocket laminated card for physicians, plus monograph on managing inherited breast cancer risk | Applicability: Developed for primary care settings | Power calculation: NR
| Underlying guidelines: USPSTF screening recommendations;AMA Monograph, Managing inherited breast cancer risk
Skinner^49^ 2005 | Tool: Cancer Risk Intake System(CRIS) | Study population: Clinic patients | Design: Uncontrolled before-after trial | Practice-related outcomes:
USA | Purpose: Risk assessment, recommendations for discussion with provider | Cancer type: Breast/ovarianColorectal | Comparison groups: None | 1. For those participants whose risk warranted a tailored tamoxifen message, pre-post change in proportion who reported discussing tamoxifen with clinician
| Content: Risk assessment algorithm Tailored printouts | Setting: Primary care | Sample size: n=215 | Pre - 4/83, Post - 23/83
| Format: Touch-screen computer application linked to printer | Applicability: Primary care | Power calculation: NR | P=0.00026 (McNemar's X^2^)
| Underlying guidelines: Expert opinion based on | | | 2. For those participants whose risk warranted a tailored cancer genetic counseling message, pre-post change in proportion who reported discussing cancer genetic counseling with clinician
| Hampel et al, J Med Genet 2004; 41: 81–91. | | | Pre - 2/71, Post - 20/71
| Burt RW, Gastroenterology 2000; 119: 837–53 | | | P=0.00012 (McNemar's X^2^)
| Winawer S et al, Gastroenterology 2003; 124: 544–60. | | | 3. For those participants whose risk warranted a tailored colonoscopy message, pre-post change in proportion who reported discussing colonoscopy with clinician
| Smith RA et al, CA Cancer J Clin 2003; 53: 27–43 | | | Pre - 5/31, Post - 14/31
| | | | P=0.0201 (McNemar's X^2^)
Watson^53^ 2001 | Tool: Information pack | Study population: Family physicians | Design: Cluster randomized controlled trial | Practice-related outcomes: Timing unclear, ‘post-intervention’; 1 Proportion of physicians making ‘correct’ referral decision for ≥ 5/6 vignettes; - Group A: 111/140 (79%); - Group B: 100/124 (81%); - Group C: 63/162 (63%); Overall p<0.001 (one way ANOVA); group A vs C - p<0.001 (X^2^); group B vs C, p<0.001 (X^2^); group A vs B, p=0.45 (X^2^); 2 Confidence scores in four aspects of managing patients with family history of cancer, 4-point Likert scale.; - Mean (SD) overall confidence scores, possible scores 0–4: Group A: 2.3 (1.0); Group B: 2.0 (1.1); Group C: 1.5 (1.0) P<0.001 (ANOVA linear trend)
Watson^54^ 2002 | Purpose: Risk assessment, clinical management | Cancer type: Breast/ovarian | Comparison groups:; 1 Tool alone; 2 None | Other outcomes reports: N/A
UK | Content: Referral guidelines; background information; patient leaflets | Setting: Family practice | Sample size: Group A - Tool plus education,
| Format: Laminated summary card plus booklet, presented as part of interactive education session | Applicability: Family practice | Practices n=56,
| Underlying guidelines: Report of the consensus meeting on the management of women with a family history of breast cancer. London: Wellcome Trust, 1998. Eccles DM et al. J Med Genet 2000; 37: 203–9 | | Physicians n=225
| | | Group B - Tool alone,
| | | Practices n=57
| | | Physicians n=233
| | | Group C - No intervention,
| | | Practices n=57
| | | Physicians n=230
| | | Power calculation: Maximum 122 physicians required per group (allowing for clustering) to detect an increase in primary outcome from 15% in Group C to 35% in Group B, or from 35% in Group B to 55% in Group A
Wilson^55^ 2005 | Tool: Multifaceted decision aid | Study population: Women consulting family physicians with queries about familial breast cancer; family physicians | Design: Cluster randomized controlled trial | Practice-related outcomes:
| Purpose: Familial cancer risk management | Cancer type: Breast, ovarian, colorectal | Comparison groups: Scottish referral guidelines mailed by Department of Health | Family physicians; 1 Self-reported physician confidence, 4-point scale; Patients; - very confident or confident taking FH - intervention group, 91/151 (60%), control group 56/92 (61%); p=0.93 (X^2^); - very confident or confident knowing who to refer - intervention group 60/151 (40%), control group 30/91 (33%); p=0.27 (X^2^); - very confident or confident reassuring low risk - intervention group 85/151 (57%), control group 48/92 (52%); p=0.46 (X^2^); - very confident or confident able to answer questions - intervention group 35/151 (23%), control group 20/92 (22%); p=0.77 (X^2^); 2 Genetic risk of referred patients; - Proportion of referred patients assessed as elevated genetic risk Intervention group 14/29 (48%), control group 22/34 (65%), NS (reported as risk ratio) N.B. Baseline differences between groups; 3 Patients' breast cancer beliefs Proportion of referred patients agreeing with ‘incorrect’ causal statement; - ‘stress always increases your risk’ intervention group 17/74 (23%), control group 5/22 (23%); p=0.98 (X^2^); - ‘Having one close relative with breast cancer always increases your risk’ - intervention group 66/75 (88%), control group 20/22 (91%); p=0.71 (X^2^); - ‘Minor injury always increases your risk’- intervention group 15/75 (20%), control group 5/22 (23%); p=0.78 (X^2^).
| Purpose: Familial cancer risk management | Cancer type: Breast, ovarian, colorectal | Comparison groups: Scottish referral guidelines mailed by Department of Health | Control group - Responders pre-intervention n=93;Responders post-intervention n=92
Wilson^56^ 2006 | Content: Targeted family history questions; risk assessment module; background information on cancer genetics; printer-friendly patient information leaflets; weblinks; email link to cancer genetics service; automated individualized referral letter | Setting: Family practice | Sample size: PhysiciansIntervention group - Responders pre-intervention n=179;Responders post-intervention n=151 | Patients Intervention group - Responders pre-intervention n=133;Responders post-intervention n=75
UK | Format: Physician-oriented personal computer package. Implemented with offer of education session | Applicability: Family practice | Power calculation: 168 interventions, 84 control practices required (2:1 allocation ratio) to detect absolute difference of 20% in physicians responding very confident or confident in attitude items, 80% power, α = 0.05, ICC 0.05 | Control group -Responders pre-intervention n=52;Responders post-intervention n=22
| Underlying guidelines: Scottish Cancer Group Cancer Genetics Sub-Group. Cancer genetics services in Scotland. Guidance to support the implementation of genetics services for breast, ovarian and colorectal cancer predisposition. Edinburgh: Scottish Executive Health Department, 2001 | | | Other outcomes measured: N/A

2 Abbreviations: AMA=American Medical Association; Chi-square= x; EsPeR=Personalized Estimate Risks; FCAT=Familial Cancer Assessment Tool; FHAT=Family History Assessment Tool; GP=General Practitioner; GRACE=Genetic Risk Assessment in the Clinical Environment; GRAIDS= Genetic Risk Assessment in an Intranet and Decision Support; ICC=Inter Class Correlation; NR=NR; PC=Primary Care; OR=Odds Ratio; RAGs=Risk Assessment in Genetics; SD=Standard deviation; USPSTF=United States Preventive Services Task Force;

## Reference List for Evidence Tables

1 Acheson LS, Zyzanski SJ, Stange KC, et al. Validation of a self-administered, computerized tool for collecting and displaying the family history of cancer. J Clin Oncol. Dec 1. 2006;24(34):5395-402. [pmid: 17088568].
2 Aitken J, Bain C, Ward M, et al. How accurate is self-reported family history of colorectal cancer?. Am J Epidemiol. 1995;141(9):863-71. [pmid: 7717363].
3 Anton-Culver H, Kurosaki T, Taylor TH, et al. Validation of family history of breast cancer and identification of the BRCA1 and other syndromes using a population-based cancer registry. Genet Epidemiol. 1996;13(2):193-205. [pmid: 8722746].
4 Breuer B, Kash KM, Rosenthal G, et al. Reporting bilaterality status in first-degree relatives with breast cancer: a validity study. Genet Epidemiol. 1993;10(4):245-56. [pmid: 8224805].
5 Eerola H, Blomqvist C, Pukkala E, et al. Familial breast cancer in southern Finland: how prevalent are breast cancer families and can we trust the family history reported by patients?. Eur J Cancer. 2000;36(9):1143-8. [pmid: 10854948].
6 Gaff CL, Aragona C, MacInnis RJ, et al. Accuracy and completeness in reporting family history of prostate cancer by unaffected men. Urology. 2004;63(6):1111-6. [pmid: 15183962].
7 Geller BM, Mickey RM, Rairikar CJ, et al. Identifying women at risk for inherited breast cancer using a mammography registry. J Cancer Educ. 2001;16(1):46-9. [pmid: 11270900].
8 Gianz K, Grove J, Le Marchand L, et al. Underreporting of family history of colon cancer: Correlates and implications. Cancer Epidemiol Biomarkers Prev. 1999;8(7):635-9. [pmid: 10428202].
9 Katballe N, Juul S, Christensen M, et al. Patient accuracy of reporting on hereditary non-polyposis colorectal cancer-related malignancy in family members. Br J Surg. 2001;88(9):1228-33. [pmid: 11531872].
10 Kerber RA, Slattery ML. Comparison of self-reported and database-linked family history of cancer data in a case-control study. Am J Epidemiol. 1997;146(3):244-8. [pmid: 9247008].
11 King TM, Tong L, Pack RJ, et al. Accuracy of family history of cancer as reported by men with prostate cancer. Urology. 2002;59(4):546-50. [pmid: 11927311].
12 Kupfer SS, McCaffrey S, Kim KE. Racial and Gender Disparities in Hereditary Colorectal Cancer Risk Assessment: The Role of Family History. J Cancer Educ. 2006;21(Suppl 1):S32-S36. [pmid: 17020499].
13 Mitchell RJ, Brewster D, Campbell H, et al. Accuracy of reporting of family history of colorectal cancer. Gut. 2004;53(2):291-5. [pmid: 14724166]. [pmcid: 1774933].
14 Parent ME, Ghadirian P, Lacroix A, et al. Accuracy of reports of familial breast cancer in a case-control series. Epidemiology. 1995;6(2):184-6. [pmid: 7742408].
15 Parent M, Ghadirian P, Lacroix A, et al. The reliability of recollections of family history: implications for the medical provider. J Cancer Educ. 1997;12(2):114-20. [pmid: 9229275].
16 Schneider KA, DiGianni LM, Patenaude AF, et al. Accuracy of cancer family histories: comparison of two breast cancer syndromes. Genet Test. 2004;8(3):222-8. [pmid: 15727243].
17 Sijmons RH, Boonstra AE, Reefhuis J, et al. Accuracy of family history of cancer: clinical genetic implications. Eur J Hum Genet. 2000;8(3):181-6. [pmid: 10780783].
18 Theis B, Boyd N, Lockwood G, et al. Accuracy of family cancer history in breast cancer patients. Eur J Cancer Prev. 1994;3(4):321-7. [pmid: 7950886].
19 Weinrich SP, Faison-Smith L, Hudson-Priest J, et al. Stability of self-reported family history of prostate cancer among African American men. J Nurs Meas. 2002;10(1):39-46. [pmid: 12048968].
20 Ziogas A, Anton-Culver H. Validation of family history data in cancer family registries. Am J Prev Med. 2003;24(2):190-8. [pmid: 12568826].
21 Emery J, Walton R, Murphy M, et al. Computer support for interpreting family histories of breast and ovarian cancer in primary care: comparative study with simulated cases.[see comment]. BMJ. 2000;321(7252):28-32. [pmid: 10875832]. [pmcid: 27423].
22 Benjamin C, Booth K, Ellis I. A Prospective Comparison Study of Different Methods of Gathering Self-Reported Family History Information for Breast Cancer Risk Assessment. J Genet Couns. Apr. 2003;12(2):151-70.
23 Braithwaite D, Sutton S, Mackay J, et al. Development of a risk assessment tool for women with a family history of breast cancer. Cancer Detect Prev. 2005;29(5):433-9. [pmid: 16055276].
24 Colombet I, Dart T, Leneveut L, et al. A computer decision aid for medical prevention: a pilot qualitative study of the Personalized Estimate of Risks (EsPeR) system. BMC Med Inform Decis Mak. 2003;3:13. [pmid: 14641924]. [pmcid: 317339].
25 Colombet I, Dart T, Leneveut L, et al. Combining risks estimations and clinical practice guidelines in a computer decision aid: a pilot study of the EsPeR system. Stud Health Technol Inform. 2003;95:525-30. [pmid: 14664040].
26 de Bock GH, Perk DC, Oosterwijk JC, et al. Women worried about their familial breast cancer risk—a study on genetic advice in general practice. Fam Pract. Feb. 1997;14(1):40-3. [pmid: 9061343].
27 Emery J, Walton R, Coulson A, et al. Computer support for recording and interpreting family histories of breast and ovarian cancer in primary care (RAGs): qualitative evaluation with simulated patients. BMJ. 1999;319(7201):32-6. [pmid: 10390458]. [pmcid: 28153].
28 Emery J. The GRAIDS Trial: the development and evaluation of computer decision support for cancer genetic risk assessment in primary care. Ann Hum Biol. 2005;32(2):218-27. [pmid: 16096220].
29 Emery J, Morris H, Goodchild R, et al. The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. Br J Cancer. Aug 14. 2007;97(4):486-93. [pmid: 17700548].
30 Fisher TJ, Kirk J, Hopper JL, et al. A simple tool for identifying unaffected women at a moderately increased or potentially high risk of breast cancer based on their family history. Breast. 2003;12(2):120-7. [pmid: 14659341].
31 Frezzo TM, Rubinstein WS, Dunham D, et al. The genetic family history as a risk assessment tool in internal medicine. Genet Med. 2003;5(2):84-91. [pmid: 12644777].
32 Grover S, Stoffel EM, Bussone L, et al. Physician assessment of family cancer history and referral for genetic evaluation in colorectal cancer patients. Clin Gastroenterol Hepatol. 2004;2(9):813-9. [pmid: 15354282].
33 House W, Sharp D, Sheridan E. Identifying and screening patients at high risk of colorectal cancer in general practice. J Med Screen. 1999;6(4):205-8. [pmid: 10693067].
34 Hughes KS, Roche C, Campbell CT, et al. Prevalence of family history of breast and ovarian cancer in a single primary care practice using a self-administered questionnaire. Breast J. 2003;9(1):19-25. [pmid: 12558666].
35 Hurt GJ, McQuellon RP, Michielutte R, et al. Risk assessment of first-degree relatives of women with breast cancer: a feasibility study. Oncol Nurs Forum. 2001;28(7):1097-104. [pmid: 11517843].
36 Kelly KM, Shedlosky-Shoemaker R, Porter K, et al. Cancer family history reporting: Impact of method and psychosocial factors. Journal of Genetic Counseling. 2007;16(3):373-82. [pmid: 17318453].
37 Murff HJ, Greevy RA, Syngal S. The comprehensiveness of family cancer history assessments in primary care. Community Genetics. 2007;10(3):174-80. [pmid: 17575462].
38 Schroy PC, Glick JT, Geller AC, et al. A novel educational strategy to enhance internal medicine residents' familial colorectal cancer knowledge and risk assessment skills. Am J Gastroenterol. 2005;100(3):677-84. [pmid: 15743368].
39 Sweet KM, Bradley TL, Westman JA. Identification and referral of families at high risk for cancer susceptibility. J Clin Oncol 2002 Jan 2;(2):
40 Yang Q, Khoury MJ, Rodriguez C, et al. Family history score as a predictor of breast cancer mortality: Prospective data from the cancer prevention study II, United States, 1982- 1991. Am J Epidemiol. 1998;147(7):652-9. [pmid: 9554604].
41 Andrieu N, Launoy G, Guillois R, et al. Estimation of the familial relative risk of cancer by site from a French population based family study on colorectal cancer (CCREF study). Gut. 2004;53(9):1322-8. [pmid: 15306593]. [pmcid: 1774179].
42 Bruner DW, Baffoe-Bonnie A, Miller S, et al. Prostate cancer risk assessment program. A model for the early detection of prostate cancer. Oncology (Huntington). 1999;13(Huntington):325-34.
43 Chalmers KI, Luker KA, Leinster SJ, et al. Information and support needs of women with primary relatives with breast cancer: development of the Information and Support Needs Questionnaire. J Adv Nurs. 2001;35(4):497-507. [pmid: 11529948].
44 De Jong AE, Vasen HF. The frequency of a positive family history for colorectal cancer: a population-based study in the Netherlands.[see comment]. Netherlands Journal of Medicine. Nov. 2006;64(10):367-70. [pmid: 17122453].
45 Fletcher RH, Lobb R, Bauer MR, et al. Screening patients with a family history of colorectal cancer. J Gen Intern Med. Apr. 2007;22(4):508-13. [pmid: 17372801]. [pmcid: 1829437].
46 Green RC, Green JS, Buehler SK, et al. Very high incidence of familial colorectal cancer in Newfoundland: A comparison with Ontario and 13 other population-based studies. Familial Cancer. 2007;6(1):53-62. [pmid: 17039269].
47 Hlavaty T, Lukac L, Huorka M, et al. Positive family history promotes participation in colorectal cancer screening. Bratisl Lek Listy. 2005;106(10):318-23. [pmid: 16541612].
48 Quillin JM, Ramakrishnan V, Borzelleca J, et al. Paternal Relatives and Family History of Breast Cancer. Am J Prev Med. 2006;31(3):265-8. [pmid: 16905040].
49 Skinner CS, Rawl SM, Moser BK, et al. Impact of the Cancer Risk Intake System on patient-clinician discussions of tamoxifen, genetic counseling, and colonoscopy. J Gen Intern Med. Apr. 2005;20(4):360-5. [pmid: 15857495]. [pmcid: 1490091].
50 Tischkowitz M, Wheeler D, France E, et al. A comparison of methods currently used in clinical practice to estimate familial breast cancer risks. Ann Oncol. 2000;11(4):451-4. [pmid: 10847465].
51 Gilpin CA, Carson N, Hunter AG. A preliminary validation of a family history assessment form to select women at risk for breast or ovarian cancer for referral to a genetics center. Clin Genet. 2000;58(4):299-308. [pmid: 11076055].
52 Gramling R, Duffy C, David S. Does providing hereditary breast cancer risk assessment support to practicing physicians decrease the likelihood of them discussing such risk with their patients?. Genet Med. 2004;6(6):542. [pmid: 15545753].
53 Watson E, Clements A, Yudkin P, et al. Evaluation of the impact of two educational interventions on GP management of familial breast/ovarian cancer cases: a cluster randomised controlled trial. Br J Gen Pract. 2001;51(471):817-21. [pmid: 11677705]. [pmcid: 1314127].
54 Watson E, Clements A, Lucassen A, et al. Education improves general practitioner (GP) management of familial breast/ovarian cancer: findings from a cluster randomised controlled trial. J Med Genet. Oct. 2002;39(10):779-81. [pmid: 12362040]. [pmcid: 1734993].
55 Wilson BJ, Torrance N, Mollison J et al. Improving the referral process for familial breast cancer genetic counselling: findings of three randomised controlled trials of two interventions. Health Technol Assess, 9 (3). The NHS Health Technology Assessment Programme; 2005.
56 Wilson BJ, Torrance N, Mollison J, et al. Cluster randomized trial of a multifaceted primary care decision-support intervention for inherited breast cancer risk. Fam Pract. Oct. 2006;23(5):537-44. [pmid: 16787957].