# Appendix B. Forms/Guides and Internet Family History Tools

To see the Forms and Guides, please select the link below. This link will take you to a PDF version of the forms and guides.

Forms and Guides

## Internet Sites Accessed

Family History Tools Available on the Internet

Title | Website address | Type
The U.S. Surgeon General's Family History Initiative | http://www.hhs.gov/familyhistory/downloads/portraitEng.pdf | Family Health Portrait - Paper Version
Department of Health and Human Services (HHS) | Website accessed on June 28^th^, 2007. | Agencies involved in this project: Human Genome Research Institute (NHGRI), the Centers for Disease Control and Prevention (CDC), the Agency for Healthcare Research and Quality (AHRQ), the American Society of Human Genetics (ASHG) the Health Resources and Services Administration (HRSA), the National Society of Genetic Counselors and the Genetic Alliance
Family Disease Checklist | http://www.genetests.org/servlet/access?id=8888892&key=TkUzWfsXb38xZ&fcn=y&fw=61uz&filename=/tools/concepts/checklist.html | Genetic Tools Website- Genetics Through a Primary Care Lens
| Website accessed on June 28^th^, 2007.
Your Family Medical History | http://www.genetests.org/servlet/access?id=8888892&key=xdmgIBahsKytS&fcn=y&fw=qgJE&filename=/tools/concepts/medHist.html | Genetic Tools Website - Genetics Through a Primary Care Lens
| Website accessed on June 28^th^, 2007.
American Medical Association Adult Family History Form | http://www.ama-assn.org/ama/pub/category/13333.html | Electronic Family History Form
| Website accessed on June 28^th^, 2007.
Myriad Tests Family History Questionnaire | http://www.myriadtests.com/doc/cancerhistory_fhq.pdf | Family History Questionnaire for Hereditary Cancers paper version
| Website accessed on June 28^th^, 2007.
Utah Department of Health | http://health.utah.gov/genomics/familyhistory/documents/Toolkit/new%20entire%20toolkit.pdf | Family History Tool Kit - paper version
| Website accessed on June 28^th^, 2007.
Norwich Union Health Tree | http://www.norwichunion.com/healthtree/index.htm | Electronic Family History Builder (pedigree)
| Website accessed on June 28^th^, 2007.
JamesLink: Personalized Cancer Risk Assessment | http://www.jamesline.com/patientsandvisitors/prevention/cancergenetics/#Start%20Session | Interactive tool that estimates cancer risk by reviewing patterns of cancer in a
Ohio State University Comprehensive Cancer Center - James Cancer Hospital and Solove Research Institute | Website accessed on June 28^th^, 2007.
The Munroe-Meyer Institute for Genetics and Rehabilitation and the Eppley Cancer Center of the University of Nebraska Medical Center | http://app1.unmc.edu/gencancer/ | Interactive Cancer Family Tree
| Website accessed on June 28^th^, 2007.
Evanston Northwestern Center for Medical Genetics | http://enh.org/clinicalservices/medicalgenetics/mygenerations/ | Interactive Family History Tools
| Website accessed on June 28^th^, 2007.
Genetic Susceptibility to Breast and Ovarian Cancer: Assessment, Counseling and Testing Guidelines American College of Medical Genetics Foundation | http://www.health.state.ny.us/nysdoh/cancer/obcancer/append11.htm | Sample Cancer Family History Questionnaire
| Website accessed on June 29^th^, 2007.

Scoring Criteria for the Family History Tools (FHT)
Attribute | Original scoring range | Corrected scoring
| | 1 = lowest score; 5 =highest score
Length of tool | 1 = too short | Score 1 = 1
| 3 = adequate size | Score 2 = 3
| 5 = too long | Score 3 = 5
| | Score 4 = 3
| | Score 5 = 1
Ease of completion | 1 = very difficult | No change
| 5 = very easy
Need specialist knowledge to complete FHT | 1 = need specialist knowledge | No change
| 5 = complete without knowledge input
Minimum collect details on ALL 1^st^ degree relatives | 1 = no details collected | No change
| 5 = details collected on all 1^st^ degree relatives
Clarity of family history collection including appropriate structure, layout & logical sequence | 1 = poor clarity | No change
| 5 = excellent clarity

Scoring of Available Family History Tool
Title | Length | Ease | Specialist knowledge | 1^st^ Degree relatives | Clarity | TOTAL Score | Comments
The U.S. Surgeon General's Family History Initiative | 3 | 4 | 5 | 5 | 3 | 20
AAFP Family Disease Checklist | 5 | 3 | 3 | 3 | 2 | 16
AAFP Your Family Medical History | 3 | 4 | 5 | 5 | 3 | 20 | Ethnicity reported
American Medical Association Adult Family History Form | 3 | 2 | 3 | 5 | 2 | 15 | Ethnicity reported
Myriad Tests Family History Questionnaire | 3 | 4 | 3 | 1 | 2 | 13
Utah Department of Health | NE | NE | NE | NE | NE | NE | NOT enough information on tool to evaluate
Norwich Union Health Tree | 3 | 4 | 5 | 3 | 2 | 17
James Link : Personalized Cancer Risk Assessment | | | | | | | Assessed as part of article by Sweet et al.*
The Munroe-Meyer Institute | 3 | 4 | 3 | 4 | 2 | 16
Evanston Northwestern Center for Medical Genetics | NE | NE | NE | NE | NE | NE | NOT enough information on tool to evaluate
Guidelines American College of Medical Genetics Foundation | 3 | 4 | 5 | 4 | 3 | 19

FHTs were independently scored by 2 assessors & any discrepancy resolved through planned consensus discussion using the criteria above

* Sweet KM, Bradley TL, Westman JA. Identification and referral of families at high risk for cancer susceptibility. Journal of Clinical Oncology 2002 Jan 2;20(2):528–37.

Abbreviations: NE=not evaluated

Reviews Available on the Internet describing Family History Tools

Title | Website address | Type
The Genetic Family History In Practice Newsletter - Spring 2005 | http://www.nchpeg.org/newsletter/inpracticespr05.pdf | NCHPEG Newsletter for Health Care Professionals
| Website accessed on June 28^th^, 2007.
The Genetic Family History In Practice Newsletter - Winter 2005 | http://www.nchpeg.org/newsletter/inpracticewinter05.pdf | NCHPEG Newsletter for Health Care Professionals
| Website accessed on June 28^th^, 2007.
The Genetic Family History In Practice Newsletter - Spring 2004 | http://www.nchpeg.org/newsletter/inpracticespr04.pdf | NCHPEG Newsletter for Health Care Professionals
| Website accessed on June 28^th^, 2007.
The Genetic Family History In Practice Newsletter - Spring 2003 | http://www.nchpeg.org/newsletter/inpracticespr03.pdf | NCHPEG Newsletter for Health Care Professionals
| Website accessed on June 28^th^, 2007.

Summary Reports/Reviews/Health Technology Assessments Available on the Internet

Title | Website address | Type
BRCA and Breast/Ovarian Cancer — Disorder Setting | http://www.cdc.gov/genomics/gtesting/file/print/FBR/BCDisSet.pdf | Draft Genetic Test Review
| Website accessed on June 28^th^, 2007.
Decision aid for the introduction of population-based genetic screening programs (work in progress). | www.aetmis.gouv.qc.ca | Agence d'évaluation des technologies et des modes d'intervention en santé (AETMIS) Report
| Website accessed on June 28^th^, 2007.
Contribution of BRCA1/2 Mutation Testing to Risk Assessment for Suceptibility to Breast and Ovarian Cancer | http://www.aetmis.gouv.qc.ca/site/download.php?f=b14cef3dbf7ba791b4bdf9557f9d4e6d | Summary Report from Agence D'Évaluation des Technologies et des Modes D'Intervention en Santé Summary Report
| Website accessed on June 28^th^, 2007.
Predictive Genetic Testing for Breast and Prostate Cancer | www.ccohta.ca | Canadian Coordinating Office for Health Technology Assessment (CCOHTA) Technology Report
| Website accessed on June 28^th^, 2007.
Molecular Diagnosis for Hereditary Cancer Predisposing Syndromes: Genetic Testing and Clinical Impact | www.ccohta.ca | Canadian Coordinating Office for Health Technology Assessment (CCOHTA) Technology Report
| Website accessed on June 28^th^, 2007.
BRCA1 and BRCA2 Predictive Genetic Testing for Breast and Ovarian Cancers: Asystematic Review of Clinical Evidence | www.ccohta.ca | Canadian Coordinating Office for Health Technology Assessment (CCOHTA) Technology Report
| Website accessed on June 28^th^, 2007.