# Appendix A. Exact Search Strings and Websites Searched

All searches updated to July 22, 2007

## Ovid MEDLINE(R)

1 Breast Neoplasms/
2 exp Colorectal Neoplasms/
3 exp Ovarian Neoplasms/
4 exp Prostatic Neoplasms/
5 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
6 or/1–5
7 (note or comment or editorial or letter).pt.
8 exp Medical History Taking/
9 exp Family/ or exp Family Health/
10 exp Pedigree/
11 limit 10 to humans
12 ((family or familial) adj3 (histor$ or history-taking or risk$)).ti,ab.
13 anamnesis.ti,ab.
14 (human adj2 pedigree).ti,ab.
15 (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
16 genogram$.mp.
17 ((famil$ or heredi$ or inherit$) adj3 (cancer$ or carcinom$ or neoplasm$)).ti,ab.
18 or/8–9,11–17
19 6 and 18
20 limit 19 to yr=“1990 - 2007”
21 20 not 7
22 exp Neoplasms/
23 cancer$.ti,ab.
24 or/22–23
25 (method$ or tool$ or form$).ti,ab.
26 ((genetic or famil$ or heredit$ or inherit$) adj2 (risk adj3 (assessment or evaluation))).ti,ab.
27 26 and 25
28 (famil$ histor$ adj3 (method$ or tool$ or form$)).ti,ab.
29 27 or 28
30 29 and 24
31 limit 30 to yr=“1990 - 2007”
32 31 not 7
33 32 or 21

## EMBASE

1 exp Neoplasms/
2 cancer$.ti,ab.
3 or/1–2
4 (method$ or tool$ or form$).ti,ab.
5 ((genetic or famil$ or heredit$ or inherit$) adj2 (risk adj3 (assessment or evaluation))).ti,ab.
6 4 and 5
7 (famil$ histor$ adj3 (method$ or tool$ or form$)).ti,ab.
8 or/6–7
9 3 and 8
10 limit 9 to yr=“1990 - 2007”
11 exp Breast Cancer/
12 exp Colon Cancer/
13 exp Ovary Cancer/
14 exp Prostate Cancer/
15 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
16 or/11–15
17 (note or comment or editorial or letter).pt.
18 exp anamnesis/
19 ((family or familial) adj3 (histor$ or history-taking or risk$)).ti,ab.
20 anamnesis.ti,ab.
21 (human adj2 pedigree).ti,ab.
22 (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
23 ((famil$ or heredi$ or inherit$) adj3 (cancer$ or carcinom$ or neoplasm$)).ti,ab.
24 genogram$.mp.
25 or/18–24
26 16 and 25
27 limit 26 to yr=“1990 - 2007”
28 27 not 17
29 10 not 17
30 or/28–29

## CINAHL - Cumulative Index to Nursing & Allied Health Literature

1 (note or comment or editorial or letter).pt.
2 exp Medical History Taking/
3 exp Family/ or exp Family Health/
4 exp Pedigree/
5 limit 4 to humans [Limit not valid in: CINAHL; records were retained]
6 ((family or familial) adj3 (histor$ or history-taking or risk$)).ti,ab.
7 anamnesis.ti,ab.
8 (human adj2 pedigree).ti,ab.
9 (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
10 ((famil$ or heredi$ or inherit$) adj3 (cancer$ or carcinom$ or neoplasm$)).ti,ab.
11 or/2–3,5–9,10
12 exp Breast Neoplasms/
13 exp Colorectal Neoplasms/
14 exp Ovarian Neoplasms/
15 exp Prostatic Neoplasms/
16 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
17 or/12–16
18 11 and 17
19 limit 18 to yr=“1990 - 2007”
20 19 not 1
21 exp Neoplasms/
22 cancer$.ti,ab.
23 or/21–22
24 (method$ or tool$ or form$).ti,ab.
25 ((genetic or famil$ or heredit$ or inherit$) adj2 (risk adj3 (assessment or evaluation))).ti,ab.
26 24 and 25
27 (famil$ histor$ adj3 (method$ or tool$ or form$)).ti,ab.
28 or/26–27
29 23 and 28
30 limit 29 to yr=“1990 - 2007”
31 30 not 1
32 20 or 31

## EBM Reviews - Cochrane Central Register of Controlled Trials

1 Breast Neoplasms/
2 exp Colorectal Neoplasms/
3 exp Ovarian Neoplasms/
4 exp Prostatic Neoplasms/
5 ((breast or ovar$ or prostate or colon or colorectal) adj3 (cancer$ or neoplasm$ or carcinom$)).ti,ab.
6 or/1–5
7 (note or comment or editorial or letter).pt.
8 exp Medical History Taking/
9 exp Family/ or exp Family Health/
10 exp Pedigree/
11 limit 10 to humans [Limit not valid; records were retained]
12 ((family or familial) adj3 (histor$ or history-taking or risk$)).ti,ab.
13 anamnesis.ti,ab.
14 (human adj2 pedigree).ti,ab.
15 (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
16 genogram$.mp.
17 ((famil$ or heredi$ or inherit$) adj3 (cancer$ or carcinom$ or neoplasm$)).ti,ab.
18 or/8–9,11–17
19 6 and 18
20 limit 19 to yr=“1990 - 2007”
21 20 not 7
22 exp Neoplasms/
23 cancer$.ti,ab.
24 or/22–23
25 (method$ or tool$ or form$).ti,ab.
26 ((genetic or famil$ or heredit$ or inherit$) adj2 (risk adj3 (assessment or evaluation))).ti,ab.
27 26 and 25
28 (famil$ histor$ adj3 (method$ or tool$ or form$)).ti,ab.
29 27 or 28
30 29 and 24
31 limit 30 to yr=“1990 - 2007”
32 31 not 7
33 32 or 21

## Internet Sites Searched

Title | Website address | Type
The Genetic Family History In Practice Newsletter - Spring 2005 | http://www.nchpeg.org/newsletter/inpracticespr05.pdf | NCHPEG Newsletter for Health Care Professionals
The Genetic Family History In Practice Newsletter - Winter 2005 | http://www.nchpeg.org/newsletter/inpracticewinter05.pdf | NCHPEG Newsletter for Health Care Professionals
The Genetic Family History In Practice Newsletter - Spring 2004 | http://www.nchpeg.org/newsletter/inpracticespr04.pdf | NCHPEG Newsletter for Health Care Professionals
The Genetic Family History In Practice Newsletter - Spring 2003 | http://www.nchpeg.org/newsletter/inpracticespr03.pdf | NCHPEG Newsletter for Health Care Professionals
Family Disease Checklist | http://www.genetests.org/servlet/access?id=8888892&key=TkUzWfsXb38xZ&fcn=y&fw=61uz&filename=/tools/concepts/checklist.html | Genetic Tools Website- Genetics Through a Primary Care Lens
Your Family Medical History | http://www.genetests.org/servlet/access?id=8888892&key=xdmgIBahsKytS&fcn=y&fw=qgJE&filename=/tools/concepts/medHist.html | Genetic Tools Website - Genetics Through a Primary Care Lens
BRCA and Breast/Ovarian Cancer — Disorder Setting | http://www.cdc.gov/genomics/gtesting/file/print/FBR/BCDisSet.pdf | Draft Genetic Test Review
American Medical Association Adult Family History Form | http://www.ama-assn.org/ama/pub/category/13333.html | Electronic Family History Form
Decision aid for the introduction of population-based genetic screening programs (work in progress). | www.aetmis.gouv.qc.ca | Agence d'évaluation des technologies et des modes d'intervention en santé (AETMIS) Report
Contribution of BRCA1/2 Mutation Testing to Risk Assessment for Suceptibility to Breast and Ovarian Cancer | http://www.aetmis.gouv.qc.ca/site/download.php?f=b14cef3dbf7ba791b4bdf9557f9d4e6d | Summary Report from Agence D'Évaluation des Technologies et des Modes D'Intervention en Santé Summary Report
Predictive Genetic Testing for Breast and Prostate Cancer | www.ccohta.ca | Canadian Coordinating Office for Health Technology Assessment (CCOHTA) Technology Report
Molecular Diagnosis for Hereditary Cancer Predisposing Syndromes: Genetic Testing and Clinical Impact | www.ccohta.ca | Canadian Coordinating Office for Health Technology Assessment (CCOHTA) Technology Report
BRCA1 and BRCA2 Predictive Genetic Testing for Breast and Ovarian Cancers: Asystematic Review of Clinical Evidence | www.ccohta.ca | Canadian Coordinating Office for Health Technology Assessment (CCOHTA) Technology Report
The U.S. Surgeon General's Family History Initiative | http://www.hhs.gov/familyhistory/downloads/portraitEng.pdf | Family Health Portrait - Paper Version