# Appendixes

Appendix A. Exact Search Strings and Websites Searched

Appendix B. Forms/Guides and Internet Family History Tools

Appendix C. Evidence Tables

Appendix D. List of Excluded Studies

Appendix E. Technical Expert Panel and Peer Reviewers