# List of Acronyms/Abbreviations

Clinical
1,25-(OH)_2_D_3_ | 1, 25-dihydroxyvitamin D_3_ or 1, 25-dihydroxycholecalciferol, calcitriol
1,25-(OH)_2_D | 1-alpha hydroxy cholecalciferol (alfacalcidiol)
25(OH)D | 25-hydroxyvitamin D (total or isoform unspecified)
25(OH)D_2_ | 25-hydroxyvitamin D_2_ or 25-hydroxyergocalciferol
25(OH)D_3_ | 25-hydroxyvitamin D_3_ or calcifediol .
AC | allocation concealment
AI | Adequate intake
AL | aluminum
AP or ALP | alkaline phosphatase
ASMM | appendicular skeletal muscle mass
AUC | area under the curve
B/w | between
BMC | bone mineral content
BMD | bone mineral density
BMI | body mass index
Ca | calcium
CACO3 | calcium carbonate
CPBA | competitive protein binding assay
Cr | creatinine
CrCl | creatinine clearance
DBP | vitamin D binding protein
def | deficient
DHC | 7-dehydrocholesterol (provitamin D_3_)
DHT | dihydrotachysterol
DPX-L | dual photon
DR | distal radius
DRI | dietary reference intakes
DXA, DEXA | dual energy x-ray absorptiometry
EAR | estimated average requirement
F | female
FFQ | Food frequency questionnaire
FN | femoral neck
FS | femoral shaft
FT | full term
GC-MS | gas chromatography coupled with mass spectometry
GS | grip strength
HPLC | high performance liquid chromatography
HRT | hormone replacement therapy
IA | immunoassay
iPTH | intact parathyroid hormone
LC-MS/MS | ligquid chromatography coupled with tandem mass spectometry
LS | lumbar spine
M | male
MED | minimal erythemal dose
Mg | magnesium
MSK | musculoskeletal
OP | osteoporosis
P | phosphate
PICP | procollagen type 1N terminal propeptide
PM | postmenopausal
pt(s) | patient(s)
PT | pre-term
RANKL | receptor activator of nuclear factor kappa beta ligand
RCT | randomized controlled trial
RDA | recommended dietary allowance
RIA | radioimmunoassay
S-AL | serum aluminum
S-Ca | serum calcium
SHBG | sex hormone binding globulin
S-phosphorus | serum phosphorus
TB | total body
TH | total hip
Tr | trochanter
TUG | timed up and go
uCa | urine calcium
uCa/Cr | urine calcium/creatinine ratio
US | ultrasound
UV | ultraviolet light
UV-B | ultraviolet light B
Vit D | vitamin D (D_2_ or D_3_ unspecified)
Vit D_2_ | vitamin D_2_ or ergocalciferol
Vit D_3_ | vitamin D_3_ or cholecalciferol
UNITS
μg | micrograms
μg /L | micrograms per liter
μg /mL | micrograms per milliliter
μg/dL | micrograms per deciliter
μmol/L | micromoles per liter
cm | centimeters
g/cm | grams per centimeter
g/cm^2^ | grams per centimeter squared
IU | international units
IU/d | international units per day
IU/L | international units per liter
kg | kilograms
kg/m^2^ | kilograms per square meter
m | meters
mg | milligrams
mg/d | milligrams per day
mJ/cm^2^ | millijoules per square centimeter
mL | milliliter
mmol/L | millimoles per liter
N | sample size
ng/dL | nanogram per deciliter
ng/L | nanogram per liter
ng/mL | nanograms per milliliter
nmol/L | nanomoles per litre
pg/mL | picograms per milliliter
IU/L | international units per liter
μm | micromolar
STATISTICS
ANCOVA | analysis of covariance
ANOVA | analysis of variance
CI | confidence interval
CV | coefficient of variation
HR | hazard ratio
IQR | Inter-quartile range
ITT | intention to treat
NS | not significant
OR | odds ratio
RR | relative risk
S | significant
SD | standard deviation
SE/SEM | standard error of the mean
COMMON TABLE ABBREVIATIONS
% | percentage
< | less than
≤ | less than or equal to
> | greater than
≥ | greater than or equal to
CG | control group
ctrls | controls
Deg | degrees
FHx | family history
h | hour
Hx | history
IG | intervention group
mo | month(s)
N | north
NA | not applicable
NR | not reported
S | south
Tx | treatment
wks | weeks
y | year