# Key Terms

## Dietary Reference Intakes^4^

Adequate Intake (AI) - an adequate intake is based on observed estimates of average nutrient intake by a group of healthy people. It is expected to meet or exceed the amount needed to maintain a defined nutritional state or criterion of adequacy in essentially all members of a specific healthy population.

For infants 0 - six months, the AI is based on the estimated daily mean intake supplied by human milk for healthy full-term infants who are exclusively breast-fed. For other age groups, the AI is the vitamin D intake value that appears to be needed to maintain, in a defined group of individuals, serum 25(OH)D at a concentration below which e.g., vitamin D deficiency rickets or osteomalacia occurs. The AI assumes no vitamin D is available from sun-mediated cutaneous synthesis.

Estimated Average Requirement (EAR) - the nutrient intake value that is estimated to meet the requirement defined by a specified indicator of adequacy in 50 percent of the individuals in a life stage and gender group. This is used to set a Recommended Daily Allowance (RDA). An EAR could not be established by the IOM in its 1997 Daily Reference Intakes for vitamin D due to insufficient data.

Recommended Dietary allowance (RDA) - the average daily dietary intake level that is sufficient to meet the nutrient requirements of nearly all (97 – 98 percent) individuals in a life stage and gender group. An EAR is the basis for setting the RDA. In the absence of sufficient data for an EAR, an AI is established.

Tolerable Upper Intake Limit - the highest level of daily intake that is likely to pose no risks of adverse health effects to almost all individuals in the general popultion.

Current Adequate Reference Intakes (IOM, 1997)^4^

Age group | Adequate Intakes
infants 0 – 13 y | 200 IU (5 ug/day)
children 14 – 18 y | 200 IU (5 ug/day)
adults 19 – 50 y | 200 IU (5 ug/day)
pregnant or lactating women (14 – 50 y) | 200 IU (5 ug/day)
adults 51 – 70 y | 400 IU (5 ug/day)
adults > 70 y | 600 IU (10 ug/day)

Vitamin D Terms

Provitamin D_3_ | 7 dehydrocholesterol (7-DHC)
Previtamin D_3_ | Synthesized in the skin from 7-dehydrocholesterol
Cholecalciferol | Vitamin D_3_. Synthesized in the skin in response to sunlight of wavelengths 290 – 320 nm (UV-B); synthesis is initiated by the photoconversion of provitamin D_3_ to previtamin D_3_.
Calcidiol | 25 hydroxycholecalciferol or calcifediol (25(OH)D_3_) - hydroxylated in the liver as the first step in the conversion of vitamin D_3_ to the active form
Calcitriol | 1,25 dihydoxyvitamin D3 (1,25-(OH)_2_D_3_), the form of vitamin D_3_ that is biologically active; produced by the hydroxylation of 25(OH)D in the kidney or at extrarenal sites.
Ergocalciferol | Vitamin D_2_, present in some naturally occuring dietary sources and in some supplements.

Conversion Factors

1 ng/mL of 25(OH)D = 2.5 nmol/L

1 ug of vitamin D = 40 IU