# References and Included Studies

1 Department of Health and Human Service. Bone health and osteoporosis: a report of the surgeon general. Rockville MD: Office of the Surgeon General; 2004.
2 Burge R, Dawson-Hughes B, Solomon DH, et al. Incidence and Economic Burden of Osteoporosis-Related Fractures in the United States, 2005-2025. J Bone Miner Res. Dec. 2006;4:465-75.
3 Melton LJ III, Atkinson EJ, O'Connor MK, et al. Determinants of bone loss from the femoral neck in women of different ages. J Bone Miner Res. 2000;15(1):24-31. [pmid: 10646111].
4 Food and Nutrition Board IoM. Vitamin D. Dietary Reference Intakes: Calcium, Phosphorus, Magnesium, Vitamin D and Fluoride. National Academic Press 1999;250–87.
5 Townsend K, Evans KN, Campbell MJ, et al. Biological actions of extra-renal 25-hydroxyvitamin D-1alpha-hydroxylase and implications for chemoprevention and treatment. J Steroid Biochem Mol Biol. Oct. 2005;97(12):103-9. [pmid: 16081283].
6 Liu PT, Stenger S, Li H, et al. Toll-like receptor triggering of a vitamin D-mediated human antimicrobial response. Science. Mar 24. 2006;311(5768):1770-3. [pmid: 16497887].
7 Lappe JM, Travers-Gustafson D, Davies KM, et al. Vitamin D and calcium supplementation reduces cancer risk: results of a randomized trial. Am J Clin Nutr. Jun. 2007;85(6):1586-91. [pmid: 17556697].
8 Cantona, M. T. Vitamin D and its role in immunology: multiple sclerosis and inflammatory bowel disease. Progress in Biophysics and Molecular Biology 200792:60–4. 2007. 6.
9 Holick MF. Vitamin D requirements for humans of all ages: new increased requirements for women and men 50 years and older. Osteoporos Int. 1998;8:S24-S29. [pmid: 10197179].
10 Holick M. Vitamin D: photobiology, metabolism, mechansim of action, and clinical applications. 5th ed. Washington DC: Humana Press; 2003.
11 Wolpowitz D, Gilchrest BA. The vitamin D questions: How much do you need and how should you get it?. J Am Acad Dermatol. 2006;54(2):301-17. [pmid: 16443061].
12 Lips P. Vitamin D physiology. Prog Biophys Mol Biol. Sep. 2006;92(1):4-8. [pmid: 16563471].
13 Goltzman D. Discoveries, drugs and skeletal disorders. Nat Rev Drug Discov. 2002;1:784-96. [pmid: 12360256].
14 Holick MF. Primer of metabolic bone diseases and disorders of mineral metabolism, vitamin D: photobiology, metabolism of action and clinical applications. 6th. 2005.
15 Specker B. Vitamin D requirements during pregnancy. Am J Clin Nutr. 2004;80(suppl):1740S-7S. [pmid: 15585798].
16 More C, Bettembuk P, Bhattoa HP, et al. The effects of pregnancy and lactation on bone mineral density. Osteoporos Int. 2001;12(9):732-7. [pmid: 11605738].
17 Karlsson MK, Ahlborg HG, Karlsson C. Female reproductive history and the skeleton-a review. BJOG. Jul. 2005;112(7):851-6. [pmid: 15957983].
18 Holick MF. Vitamin D: importance in the prevention of cancers, type I diabetes, heart disease and osteoporosis. Am J Clin Nutr. 2004;79(3):362-3. [pmid: 14985208].
19 Rucker D, Allan JA, Fick GH, et al. Vitamin D insufficiency in a population of healthy western Canadians. CMAJ. Jun 11. 2002;166(12):1517-24. [pmid: 12074117]. [pmcid: 113796].
20 Tangpricha V, Pearce EN, Chen TC, et al. Vitamin D insufficiency among free-living healthy young adults. Am J Med. Jun 1. 2002;112(8):659-62. [pmid: 12034416].
21 Looker AC, Dawson-Hughes B, Calvo MS, et al. Serum 25-hydroxyvitamin D status of adolescents and adults in two seasonal subpopulations from NHANES III. Bone. May. 2002;30(5):771-7. [pmid: 11996918].
22 Nesby-O'Dell S, Scanlon KS, Cogswell ME, et al. Hypovitaminosis D prevalence and determinants among African American and white women of reproductive age: third National Health and Nutrition Examination Survey, 1988-1994. Am J Clin Nutr. Jul. 2002;76(1):187-92. [pmid: 12081833].
23 Wharton B, Bishop N. Rickets. Lancet. 2003;362:1389-400. [pmid: 14585642].
24 Weisberg P, Scanlon KS, Li R, et al. Nutritional rickets among children in the United States: review of cases reported between 1986 and 2003. Am J Clin Nutr. Dec. 2004;80(6 Suppl):1697S-705S. [pmid: 15585790].
25 Spence JT, Serwint JR. Secondary prevention of vitamin D-deficiency rickets. Pediatrics. Jan. 2004;113(1 Pt 1):e70-e72. [pmid: 14702451].
26 Ward LM. Vitamin D deficiency in the 21st century: a persistent problem among Canadian infants and mothers. Can Med Assoc J. Mar 15. 2005;172(6):769-70. [pmid: 15767611]. [pmcid: 552891].
27 Binet A, Kooh SW. Persistence of Vitamin D-deficiency rickets in Toronto in the 1990s. Can J Public Health. Jul. 1996;87(4):227-30. [pmid: 8870299].
28 Wagner CL, Hulsey TC, Fanning D, et al. High-dose vitamin D3 supplementation in a cohort of breastfeeding mothers and their infants: a 6-month follow-up pilot study. Breastfeeding Medicine. 2006;1(2):49.
29 LeBoff MS, Kohlmeier L, Hurwitz S, et al. Occult vitamin D deficiency in postmenopausal US women with acute hip fracture. JAMA. Apr 28. 1999;281(16):1505-11. [pmid: 10227320].
30 Heaney RP, Dowell MS, Hale CA, et al. Calcium absorption varies within the reference range for serum 25-hydroxyvitamin D. J Am College of Nutrition. 2003;22(2):142-6.
31 Lips P. Vitamin D deficiency and secondary hyperparathyroidism in the elderly: consequences for bone loss and fractures and therapeutic implications. Endocr Rev. Aug. 2001;22(4):477-501. [pmid: 11493580].
32 Vieth R, Ladak Y, Walfish PG. Age-related changes in the 25-hydroxyvitamin D versus parathyroid hormone relationship suggest a different reason why older adults require vitamin D. J Clin Endocrinol Metabol 2004;185–91.
33 Scharla SH, Wolf S, Dull R, et al. Prevalence of low bone mass and endocrine disorders in hip fracture patients in Southern Germany. Exp Clin Endocrinol Diabetes. 1999;107(8):547-54. [pmid: 10612486].
34 Weatherall M. A meta-analysis of 25 hydroxyvitamin D in older people with fracture of the proximal femur. N Z Med J. Apr 28. 2000;113(1108):137-40. [pmid: 10872433].
35 Thomas MK, Lloyd-Jones DM, Thadhani RI. Hypovitaminosis D in medical inpatients. N Engl J Med. 1998;338:777-83. [pmid: 9504937].
36 Gloth FM III, Gundberg CM, Hollis BW, et al. Vitamin D deficiency in homebound elderly persons. JAMA. Dec 6. 1995;274(21):1683-6. [pmid: 7474272].
37 Glerup H, Mikkelsen K, Poulsen L, et al. Commonly recommended daily intake of vitamin D is not sufficient if sunlight exposure is limited. J Intern Med. Feb. 2000;247(2):260-8. [pmid: 10692090].
38 Thomas MK, Lloyd-Jones DM, Thadhani RI, et al. Hypovitaminosis D in medical inpatients.[see comment]. N Engl J Med. Mar. 1998;338(12):777-83. [pmid: 9504937].
39 Heaney RP, Dowell MS, Hale CA, et al. Calcium absorption varies within the reference range for serum 25-hydroxyvitamin D. J Am Coll Nutr. Apr. 2003;22(2):142-6. [pmid: 12672710].
40 Barger-Lux MJ, Heaney RP. Effects of above average summer sun exposure on serum 25-hydroxyvitamin D and calcium absorption. J Clin Endocrinol Metab. Nov. 2002;87(11):4952-6. [pmid: 12414856].
41 Dawson-Hughes B, Heaney RP, Holick MF, et al. Estimates of optimal vitamin D status. Osteoporos Int. 2005;16(7):713-6. [pmid: 15776217].
42 Bischoff-Ferrari HA, Dietrich T, Orav EJ, et al. Positive association between 25-hydroxy vitamin D levels and bone mineral density: a population-based study of younger and older adults. Am J Med. May 1. 2004;116(9):634-9. [pmid: 15093761].
43 von Muhlen DG, Greendale GA, Garland CF, et al. Vitamin D, parathyroid hormone levels and bone mineral density in community-dwelling older women: the Rancho Bernardo Study. Osteoporos Int. Dec. 2005;16(12):1721-6. [pmid: 15928802].
44 Lips P, Duong T, Oleksik A, et al. A global study of vitamin D status and parathyroid function in postmenopausal women with osteoporosis: baseline data from the multiple outcomes of raloxifene evaluation clinical trial. J Clin Endocrinol Metab. Mar. 2001;86(3):1212-21. [pmid: 11238511].
45 Devine A, Wilson SG, Dick IM, et al. Effects of vitamin D metabolites on intestinal calcium absorption and bone turnover in elderly women. Am J Clin Nutr. Feb. 2002;75(2):283-8. [pmid: 11815319].
46 Hollis BW, Horst RL. The assessment of circulating 25(OH)D and 1,25(OH)(2)D: Where we are and where we are going. J Steroid Biochem Mol Biol 2006 Dec 29;
47 Saenger AK, Laha TJ, Bremner DE, et al. Quantification of serum 25-hydroxyvitamin D(2) and D(3) using HPLC-tandem mass spectrometry and examination of reference intervals for diagnosis of vitamin D deficiency. Am J Clin Pathol. Jun. 2006;125(6):914-20. [pmid: 16690491].
48 Maunsell Z, Wright DJ, Rainbow SJ. Routine isotope-dilution liquid chromatography-tandem mass spectrometry assay for simultaneous measurement of the 25-hydroxy metabolites of vitamins D. Clin Chem. 2005;51(9):1683-90. [pmid: 16020493].
49 Vogeser M, Kyriatsoulis A, Huber E, et al. Candidate reference method for the quantification of circulating 25-hydroxyvitamin D3 by liquid chromatography-tandem mass spectrometry. Clin Chem. Aug. 2004;50(8):1415-7. [pmid: 15277348].
50 Carter GD, Carter R, Jones J, et al. How accurate are assays for 25-hydroxyvitamin D? Data from the international vitamin D external quality assessment scheme. Clin Chem. 2004;50(11):2195-7. [pmid: 15375018].
51 Carter GD, Carter CR, Gunter E, et al. Measurement of Vitamin D metabolites: an international perspective on methodology and clinical interpretation. J Steroid Biochem Mol Biol. May. 2004;89–90(15):467-71.
52 Binkley N, Krueger D, Cowgill CS, et al. Assay variation confounds the diagnosis of hypovitaminosis D: a call for standardization.[see comment]. J Clin Endocrinol Metab. Jul. 2004;89(7):3152-7. [pmid: 15240586].
53 Lips P, Chapuy MC, Dawson-Hughes B, et al. An international comparison of serum 25-hydroxyvitamin D measurements.[see comment]. Osteoporos Int. 1999;9(5):394-7. [pmid: 10550457].
54 Hollis BW. Comparison of commercially available (125)I-based RIA methods for the determination of circulating 25-hydroxyvitamin D. Clin Chem. Oct. 2000;46(10):1657-61. [pmid: 11017946].
55 Carter GD, Jones JC, Berry JL. The anomalous behaviour of exogenous 25-hydroxyvitamin D in competitive binding assays. J Steroid Biochem Mol Biol. Mar. 2007;103(35):480-2. [pmid: 17197167].
56 Hollis BW. Editorial: The determination of circulating 25-hydroxyvitamin D: no easy task. J Clin Endocrinol Metab. Jul. 2004;89(7):3149-51. [pmid: 15240585].
57 Lensmeyer GL, Wiebe DA, Binkley N, et al. HPLC method for 25-hydroxyvitamin D measurement: comparison with contemporary assays. Clin Chem. Jun. 2006;52(6):1120-6. [pmid: 16574756].
58 Glendenning P, Noble JM, Taranto M, et al. Issues of methodology, standardization and metabolite recognition for 25-hydroxyvitamin D when comparing the DiaSorin radioimmunoassay and the Nichols Advantage automated chemiluminescence protein-binding assay in hip fracture cases. Ann Clin Biochem. Sep. 2003;40(Pt 5):546-51. [pmid: 14503993].
59 Glendenning P, Taranto M, Noble JM, et al. Current assays overestimate 25-hydroxyvitamin D3 and underestimate 25-hydroxyvitamin D2 compared with HPLC: need for assay-specific decision limits and metabolite-specific assays. Ann Clin Biochem. Jan. 2006;43(Pt 1):23-30. [pmid: 16390606].
60 Heaney RP, Davies KM, Chen TC, et al. Human serum 25-hydroxycholecalciferol response to extended oral dosing with cholecalciferol. Am J Clin Nutr. Jan. 2003;77(1):204-10. [pmid: 12499343].
61 Armas LA, Hollis BW, Heaney RP. Vitamin D2 is much less effective than vitamin D3 in humans. J Clin Endocrinol Metab. Nov. 2004;89(11):5387-91. [pmid: 15531486].
62 Houghton LA, Vieth R. The case against ergocalciferol (vitamin D2) as a vitamin supplement. Am J Clin Nutr. Oct. 2006;84(4):694-7. [pmid: 17023693].
63 Gartner LM, Greer FR. Prevention of rickets and vitamin D deficiency: new guidelines for vitamin D intake. Pediatrics. Apr. 2003;111(4 Pt 1):908-10. [pmid: 12671133].
64 U.S. Department of Health and Human Services and U.S. Department of Agriculture. Dietary Guidelines for Americans, 2005 6th Edition, Washington, DC: U S Government Printing Office 2005 Jan 1;
65 Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. Jul 19. 1997;350(9072):185-6. [pmid: 9250191].
66 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
67 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. Feb 1. 1995;273(5):408-12. [pmid: 7823387].
68 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
69 Lohr KN. Rating the strength of scientific evidence: relevance for quality improvement programs. Int J Qual Health Care. Feb. 2004;16(1):9-18. [pmid: 15020556].
70 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
71 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep 6. 2003;327(7414):557-60. [pmid: 12958120]. [pmcid: 192859].
72 Fleiss JL. The statistical basis of meta-analysis. Stat Methods Med Res. 1993;2(2):121-45. [pmid: 8261254].
73 Deeks JJ, Higgins JP, Altman DG. Analysing and presenting results. In: Cochrane Handbook for Systematic Reviews of Interventions, 4.2.6 2006. 8 p. 97–165.
74 Egger M, Davey SG, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. Sep 13. 1997;315(7109):629-34. [pmid: 9310563]. [pmcid: 2127453].
75 Lau J, Ioannidis JP, Terrin N, et al. The case of the misleading funnel plot. BMJ. Sep 16. 2006;333(7568):597-600. [pmid: 16974018]. [pmcid: 1570006].
76 Sterne JA, Egger M. Funnel plots for detecting bias in meta-analysis: guidelines on choice of axis. J Clin Epidemiol. Oct. 2001;54(10):1046-55. [pmid: 11576817].
77 Cesur Y, Caksen H, Gundem A, et al. Comparison of low and high dose of vitamin D treatment in nutritional vitamin D deficiency rickets. J Pediatr Endocrinol. Oct. 2003;16(8):1105-9.
78 Garabedian M, Vainsel M, Mallet E, et al. Circulating vitamin D metabolite concentrations in children with nutritional rickets. J Pediatr. Sep. 1983;103(3):381-6. [pmid: 6604146].
79 Markestad T, Halvorsen S, Halvorsen KS, et al. Plasma concentrations of vitamin D metabolites before and during treatment of vitamin D deficiency rickets in children. Acta Paediatr Scand. Mar. 1984;73(2):225-31. [pmid: 6331057].
80 Bhimma R, Pettifor JM, Coovadia HM, et al. Rickets in black children beyond infancy in Natal. South African Med J. Jul. 1995;85(7):668-72.
81 Elzouki AY, Markestad T, Elgarrah M, et al. Serum concentrations of vitamin D metabolites in rachitic Libyan children. J Pediatr Gastroenterol Nutr. Nov. 1989;9(4):507-12. [pmid: 2621528].
82 Arnaud SB, Stickler GB, Haworth JC. Serum 25-hydroxyvitamin D in infantile rickets. Pediatrics. Feb. 1976;57(2):221-5. [pmid: 175345].
83 Thacher T. Rickets without vitamin D deficiency in Nigerian children. Am Child Health. 1997;3(1 Pt 1):56-64.
84 Thacher TD, Fischer PR, Pettifor JM, et al. Case-control study of factors associated with nutritional rickets in Nigerian children. J Pediatr. Sep. 2000;137(3):367-73. [pmid: 10969262].
85 Majid MA, Badawi MH, al Yaish S, et al. Risk factors for nutritional rickets among children in Kuwait. Pediatr Int. Jun. 2000;42(3):280-4. [pmid: 10881586].
86 Balasubramanian K, Rajeswari J, Gulab, et al. Varying role of vitamin D deficiency in the etiology of rickets in young children vs. adolescents in northern India. J Trop Pediatr. Aug. 2003;49(4):201-6. [pmid: 12929879].
87 Graff M, Thacher TD, Fischer PR, et al. Calcium absorption in Nigerian children with rickets. Am J Clin Nutr. Nov. 2004;80(5):1415-21. [pmid: 15531695].
88 Dawodu A, Agarwal M, Sankarankutty M, et al. Higher prevalence of vitamin D deficiency in mothers of rachitic than nonrachitic children. J Pediatr. Jul. 2005;147(1):109-11. [pmid: 16027707].
89 Oginni LM, Worsfold M, Oyelami OA, et al. Etiology of rickets in Nigerian children. J Pediatr. May. 1996;128(5 Pt 1):692-4. [pmid: 8627444].
90 Specker BL, Ho ML, Oestreich A, et al. Prospective study of vitamin D supplementation and rickets in China. J Pediatr. May. 1992;120(5):733-9. [pmid: 1578308].
91 Zeghoud F, Vervel C, Guillozo H, et al. Subclinical vitamin D deficiency in neonates: definition and response to vitamin D supplements. Am J Clin Nutr. Mar. 1997;65(3):771-8. [pmid: 9062528].
92 Greer FR, Marshall S. Bone mineral content, serum vitamin D metabolite concentrations, and ultraviolet B light exposure in infants fed human milk with and without vitamin D2 supplements. J Pediatr. Feb. 1989;114(2):204-12. [pmid: 2783734].
93 Greer FR, Searcy JE, Levin RS, et al. Bone mineral content and serum 25-hydroxyvitamin D concentrations in breast-fed infants with and without supplemental vitamin D: one-year follow-up. J Pediatr. Jun. 1982;100(6):919-22. [pmid: 6979622].
94 Okonofua F, Menon RK, Houlder S, et al. Parathyroid hormone and neonatal calcium homeostasis: evidence for secondary hyperparathyroidism in the Asian neonate. Metabolism. Sep. 1986;35(9):803-6. [pmid: 3747837].
95 Namgung R, Tsang RC, Lee C, et al. Low total body bone mineral content and high bone resorption in Korean winter-born versus summer-born newborn infants. J Pediatr. Mar. 1998;132(3 Pt 1):421-5. [pmid: 9544894].
96 Park MJ, Namgung R, Kim DH, et al. Bone mineral content is not reduced despite low vitamin D status in breast milk-fed infants versus cow's milk based formula-fed infants. J Pediatr. Apr. 1998;132(4):641-5. [pmid: 9580763].
97 Bougle D, Sabatier JP, Bureau F, et al. Relationship between bone mineralization and aluminium in the healthy infant. Eur J Clin Nutr. Jun. 1998;52(6):431-5. [pmid: 9683396].
98 Souberbielle JC, Friedlander G, Cormier C. Practical considerations in PTH testing. [Review] [84 refs]. Clin Chim Acta. Apr. 2006;366(12):81-9. [pmid: 16310759].
99 Tanner JM, Whitehouse RH. Clinical longitudinal standards for height, weight, height velocity, weight velocity, and stages of puberty. Arch Dis Child. Mar. 1976;51(3):170-9. [pmid: 952550]. [pmcid: 1545912].
100 Rajakumar K, Fernstrom JD, Janosky JE, et al. Vitamin D insufficiency in preadolescent African-American children. Clin Pediatr (Phila). Oct. 2005;44(8):683-92. [pmid: 16211192].
101 Javaid MK, Crozier SR, Harvey NC, et al. Maternal vitamin D status during pregnancy and childhood bone mass at age 9 years: a longitudinal study. Lancet. Jan 7. 2006;367(9504):36-43. [pmid: 16399151].
102 Ala-Houhala M, Koskinen T, Koskinen M, et al. Double blind study on the need for vitamin D supplementation in prepubertal children. Acta Paediatr Scand. Jan. 1988;77(1):89-93. [pmid: 3285637].
103 Lehtonen-Veromaa MK, Mottonen TT, Nuotio IO, et al. Vitamin D and attainment of peak bone mass among peripubertal Finnish girls: a 3-y prospective study. Am J Clin Nutr. Dec. 2002;76(6):1446-53. [pmid: 12450915].
104 Guillemant J, Taupin P, Le HT, et al. Vitamin D status during puberty in French healthy male adolescents. Osteoporos Int. 1999;10(3):222-5. [pmid: 10525714].
105 Fuleihan GEH, Nabulsi M, Tamim H, et al. Effect of vitamin D replacement on musculoskeletal parameters in school children: A randomized controlled trial. J Clin Endocrinol Metab. 2006;91(2):405-12. [pmid: 16278262].
106 Marwaha RK, Tandon N, Reddy DR, et al. Vitamin D and bone mineral density status of healthy schoolchildren in northern India. Am J Clin Nutr. Aug. 2005;82(2):477-82. [pmid: 16087996].
107 Prentice A. Calcium in pregnancy and lactation. Annu Rev Nutr. 2000;20:249-72. [pmid: 10940334].
108 Sowers M, Zhang D, Hollis BW, et al. Role of calciotrophic hormones in calcium mobilization of lactation. Am J Clin Nutr. Feb. 1998;67(2):284-91. [pmid: 9459377].
109 Ardawi MS, Nasrat HA, BA'Aqueel HS. Calcium-regulating hormones and parathyroid hormone-related peptide in normal human pregnancy and postpartum: a longitudinal study. Eur J Endocrin. Oct. 1997;137(4):402-9.
110 Morley R, Carlin JB, Pasco JA, et al. Maternal 25-hydroxyvitamin D and parathyroid hormone concentrations and offspring birth size. J Clin Endocrinol Metab. Mar. 2006;91(3):906-12. [pmid: 16352684].
111 Datta S, Alfaham M, Davies DP, et al. Vitamin D deficiency in pregnant women from a non-European ethnic minority population—an interventional study. BJOG. Aug. 2002;109(8):905-8. [pmid: 12197370].
112 Corless D, Dawson E, Fraser F, et al. Do vitamin D supplements improve the physical capabilities of elderly hospital patients?. Age Ageing. Mar. 1985;14(2):76-84. [pmid: 4003187].
113 Kenny AM, Biskup B, Robbins B, et al. Effects of vitamin D supplementation on strength, physical function, and health perception in older, community-dwelling men. J Am Geriatr Soc. Dec. 2003;51(12):1762-7. [pmid: 14687355].
114 Bischoff HA, Stahelin HB, Dick W, et al. Effects of vitamin D and calcium supplementation on falls: a randomized controlled trial. J Bone Miner Res. Feb. 2003;18(2):343-51. [pmid: 12568412].
115 Dhesi JK, Jackson SHD, Bearne LM, et al. Vitamin D supplementation improves neuromuscular function in older people who fall. Age Ageing. 2004;33(6):589-95. [pmid: 15501836].
116 Storm D, Eslin R, Porter ES, et al. Calcium supplementation prevents seasonal bone loss and changes in biochemical markers of bone turnover in elderly New England women: a randomized placebo-controlled trial. J Clin Endocrinol Metab. Nov. 1998;83(11):3817-25. [pmid: 9814452].
117 Aloia JF, Talwar SA, Pollack S, et al. A randomized controlled trial of vitamin D3 supplementation in African American women. Arch Intern Med. Jul 25. 2005;165(14):1618-23. [pmid: 16043680]. [pmcid: 1464166].
118 Dawson-Hughes B, Harris SS, Krall EA, et al. Rates of bone loss in postmenopausal women randomly assigned to one of two dosages of vitamin D. Am J Clin Nutr. May. 1995;61(5):1140-5. [pmid: 7733040].
119 Ooms ME, Roos JC, Bezemer PD, et al. Prevention of bone loss by vitamin D supplementation in elderly women: a randomized double-blind trial. J Clin Endocrinol Metab. Apr. 1995;80(4):1052-8. [pmid: 7714065].
120 Cooper L, Clifton-Bligh PB, Nery ML, et al. Vitamin D supplementation and bone mineral density in early postmenopausal women. Am J Clin Nutr. May. 2003;77(5):1324-9. [pmid: 12716689].
121 Schaafsma A, van Doormaal JJ, Muskiet FA, et al. Positive effects of a chicken eggshell powder-enriched vitamin-mineral supplement on femoral neck bone mineral density in healthy late post-menopausal Dutch women. Br J Nutr. Mar. 2002;87(3):267-75. [pmid: 12064336].
122 Sambrook PN, Chen JS, March LM, et al. Serum parathyroid hormone predicts time to fall independent of vitamin D status in a frail elderly population. J Clin Endocrinol Metab. Apr. 2004;89(4):1572-6. [pmid: 15070914].
123 Flicker L, Mead K, MacInnis RJ, et al. Serum vitamin D and falls in older women in residential care in Australia. J Am Geriatr Soc. Nov. 2003;51(11):1533-8. [pmid: 14687381].
124 Visser M, Deeg DJ, Lips P, et al. Low vitamin D and high parathyroid hormone levels as determinants of loss of muscle strength and muscle mass (sarcopenia): the Longitudinal Aging Study Amsterdam. J Clin Endocrinol Metab. Dec. 2003;88(12):5766-72. [pmid: 14671166].
125 Verreault R, Semba RD, Volpato S, et al. Low serum vitamin D does not predict new disability or loss of muscle strength in older women.[see comment]. J Am Geriatr Soc. May. 2002;50(5):912-7. [pmid: 12028180].
126 Melin A, Wilske J, Ringertz H, et al. Seasonal variations in serum levels of 25-hydroxyvitamin D and parathyroid hormone but no detectable change in femoral neck bone density in an older population with regular outdoor exposure. J Am Geriatr Soc. Sep. 2001;49(9):1190-6. [pmid: 11559378].
127 Dennison E, Eastell R, Fall CH, et al. Determinants of bone loss in elderly men and women: a prospective population-based study. Osteoporos Int. 1999;10(5):384-91. [pmid: 10591836].
128 Stone K, Bauer DC, Black DM, et al. Hormonal predictors of bone loss in elderly women: a prospective study. The Study of Osteoporotic Fractures Research Group. J Bone Miner Res. Jul. 1998;13(7):1167-74. [pmid: 9661081].
129 del Puente A, Esposito A, Savastano S, et al. Dietary calcium intake and serum vitamin D are major determinants of bone mass variations in women. A longitudinal study. Aging Clin Exp Res. 2002;14(5):382-8. [pmid: 12602573].
130 Woo J, Lau E, Swaminathan R, et al. Biochemical predictors for osteoporotic fractures in elderly Chinese—a longitudinal study. Gerontology. 1990;36(1):55-8. [pmid: 2384226].
131 Gerdhem P, Ringsberg KA, Obrant KJ, et al. Association between 25-hydroxy vitamin D levels, physical activity, muscle strength and fractures in the prospective population-based OPRA Study of Elderly Women. Osteoporos Int 2005 Mar 3;
132 Bischoff-Ferrari HA, Zhang Y, Kiel DP, et al. Positive association between serum 25-hydroxyvitamin D level and bone density in osteoarthritis. Arthritis Rheum. Dec 15. 2005;53(6):821-6. [pmid: 16342101].
133 Cummings SR, Browner WS, Bauer D, et al. Endogenous Hormones and the Risk of Hip and Vertebral Fractures Among Older Women. N Engl J Med. 2006;339(11):733-8. [pmid: 9731089].
134 Faulkner KA, Cauley JA, Zmuda JM, et al. Higher 1,25-dihydroxyvitamin D3 concentrations associated with lower fall rates in older community-dwelling women. Osteoporos Int. 2006;17(9):1318-28. [pmid: 16788853].
135 Rosen CJ, Morrison A, Zhou H, et al. Elderly women in northern New England exhibit seasonal changes in bone mineral density and calciotropic hormones. Bone Miner. May. 1994;25(2):83-92. [pmid: 8086854].
136 Yan L, Zhou B, Wang X, et al. Older people in China and the United Kingdom differ in the relationships among parathyroid hormone, vitamin D, and bone mineral status. Bone. Oct. 2003;33(4):620-7. [pmid: 14555267].
137 Erem C, Tanakol R, Alagol F, et al. Relationship of bone turnover parameters, endogenous hormones and vit D deficiency to hip fracture in elderly postmenopausal women. Int J Clin Pract. Jun. 2002;56(5):333-7. [pmid: 12137439].
138 Stein MS, Wark JD, Scherer SC, et al. Falls relate to vitamin D and parathyroid hormone in an Australian nursing home and hostel. J Am Geriatr Soc. Oct. 1999;47(10):1195-201. [pmid: 10522952].
139 Boonen S, Mohan S, Dequeker J, et al. Down-regulation of the serum stimulatory components of the insulin-like growth factor (IGF) system (IGF-I, IGF-II, IGF binding protein [BP]-3, and IGFBP-5) in age-related (type II) femoral neck osteoporosis. J Bone Miner Res. Dec. 1999;14(12):2150-8. [pmid: 10620075].
140 Landin-Wilhelmsen K, Wilhelmsen L, Bengtsson BA. Postmenopausal osteoporosis is more related to hormonal aberrations than to lifestyle factors. Clin Endocrinol (Oxf ). Oct. 1999;51(4):387-94. [pmid: 10583303].
141 Thiebaud D, Burckhardt P, Costanza M, et al. Importance of albumin, 25(OH)-vitamin D and IGFBP-3 as risk factors in elderly women and men with hip fracture. Osteoporos Int. 1997;7(5):457-62. [pmid: 9425504].
142 Boonen S, Broos P, Verbeke G, et al. Calciotropic hormones and markers of bone remodeling in age-related (type II) femoral neck osteoporosis: alterations consistent with secondary hyperparathyroidism-induced bone resorption. J Gerontol A Biol Sci Med Sci. Sep. 1997;52(5):M286-M293. [pmid: 9310082].
143 Villareal DT, Civitelli R, Chines A, et al. Subclinical vitamin D deficiency in postmenopausal women with low vertebral bone mass. J Clin Endocrinol Metab. Mar. 1991;72(3):628-34. [pmid: 1997517].
144 Lau EM, Woo J, Swaminathan R, et al. Plasma 25-hydroxyvitamin D concentration in patients with hip fracture in Hong Kong. Gerontology. 1989;35(4):198-204. [pmid: 2583533].
145 Cooper C, Mclaren M, Wood PJ, et al. Indices of calcium metabolism in women with hip fractures. Bone Miner. Jan. 1989;5(2):193-200. [pmid: 2784069].
146 Lips P, van Ginkel FC, Jongen MJ, et al. Determinants of vitamin D status in patients with hip fracture and in elderly control subjects. Am J Clin Nutr. Dec. 1987;46(6):1005-10. [pmid: 3687818].
147 Lips P, Hackeng WH, Jongen MJ, et al. Seasonal variation in serum concentrations of parathyroid hormone in elderly people. J Clin Endocrinol Metab. Jul. 1983;57(1):204-6. [pmid: 6853678].
148 Punnonen R, Salmi J, Tuimala R, et al. Vitamin D deficiency in women with femoral neck fracture. Maturitas. Dec. 1986;8(4):291-5. [pmid: 3494904].
149 Lund B, Sorensen OH, Christensen AB. 25-Hydroxycholecaliferol and fractures of the proximal. Lancet. Aug 16. 1975;2(7929):300-2. [pmid: 50509].
150 Diamond T, Smerdely P, Kormas N, et al. Hip fracture in elderly men: the importance of subclinical vitamin D deficiency and hypogonadism. Med J Aust. Aug 3. 1998;169(3):138-41. [pmid: 9734509].
151 Bakhtiyarova S, Lesnyak O, Kyznesova N, et al. Vitamin D status among patients with hip fracture and elderly control subjects in Yekaterinburg, Russia. Osteoporos Int. 2006;17(3):441-6. [pmid: 16328605].
152 Al-oanzi ZH, Tuck SP, Raj N, et al. Assessment of vitamin D status in male osteoporosis. Clin Chem. Feb. 2006;52(2):248-54. [pmid: 16339300].
153 Dixon LB, McKenzie J, Shannon BM, et al. The effect of changes in dietary fat on the food group and nutrient intake of 4- to 10-year-old children. Pediatrics. Nov. 1997;100(5):863-72. [pmid: 9346988].
154 Lilliu H, Pamphile R, Chapuy MC, et al. Calcium-vitamin D3 supplementation is cost-effective in hip fractures prevention. Maturitas. Apr 25. 2003;44(4):299-305. [pmid: 12697371].
155 Chee WS, Suriah AR, Chan SP, et al. The effect of milk supplementation on bone mineral density in postmenopausal Chinese women in Malaysia. Osteoporos Int. Oct. 2003;14(10):828-34. [pmid: 12915959].
156 Keane EM, Healy M, O'Moore R, et al. Vitamin D-fortified liquid milk: benefits for the elderly community-based population. Calcif Tissue Int. Apr. 1998;62(4):300-2. [pmid: 9504953].
157 Lau EM, Woo J, Lam V, et al. Milk supplementation of the diet of postmenopausal Chinese women on a low calcium intake retards bone loss. J Bone Miner Res. Sep. 2001;16(9):1704-9. [pmid: 11547841].
158 McKenna MJ, Freaney R, Byrne P, et al. Safety and efficacy of increasing wintertime vitamin D and calcium intake by milk fortification. Qjm. Dec. 1995;88(12):895-8. [pmid: 8593549].
159 Palacios S, Castelo-Branco C, Cifuentes I, et al. Changes in bone turnover markers after calcium-enriched milk supplementation in healthy postmenopausal women: a randomized, double-blind, prospective clinical trial. Menopause. Jan. 2005;12(1):63-8. [pmid: 15668602].
160 Tangpricha V, Koutkia P, Rieke SM, et al. Fortification of orange juice with vitamin D: a novel approach for enhancing vitamin D nutritional health. Am J Clin Nutr. Jun. 2003;77(6):1478-83. [pmid: 12791627].
161 Johnson JL, Mistry VV, Vukovich MD, et al. Bioavailability of vitamin D from fortified process cheese and effects on vitamin D status in the elderly. J Dairy Sci. Jul. 2005;88(7):2295-301. [pmid: 15956292].
162 Chan GM, Hoffman K, McMurry M. Effects of dairy products on bone and body composition in pubertal girls. J Pediatr. Apr. 1995;126(4):551-6. [pmid: 7699532].
163 Daly RM, Brown M, Bass S, et al. Calcium- and vitamin D3-fortified milk reduces bone loss at clinically relevant skeletal sites in older men: a 2-year randomized controlled trial. J Bone Miner Res. Mar. 2006;21(3):397-405. [pmid: 16491287].
164 Natri AM, Salo P, Vikstedt T, et al. Bread fortified with cholecalciferol increases the serum 25-hydroxyvitamin D concentration in women as effectively as a cholecalciferol supplement. J Nutr. Jan. 2006;136(1):123-7. [pmid: 16365070].
165 Panunzio MF, Pisano A, Telesforob P, et al. Diet can increase 25-hydroxyvitamin-D3 plasma levels in the elderly: A dietary intervention trial. Nutr Res. 2003;23(9):1177-81.
166 de Jong N, Chin APM, De Groot LC, et al. Functional biochemical and nutrient indices in frail elderly people are partly affected by dietary supplements but not by exercise. J Nutr. Nov. 1999;129(11):2028-36. [pmid: 10539780].
167 Chel VG, Ooms ME, Popp-Snijders C, et al. Ultraviolet irradiation corrects vitamin D deficiency and suppresses secondary hyperparathyroidism in the elderly. J Bone Miner Res. Aug. 1998;13(8):1238-42. [pmid: 9718191].
168 Lovell GA, Byth JL, Craswell PW, et al. The influence of sunlight or dietary vitamin D on plasma 25-hydroxyvitamin D in institutionalized elderly patients in a sub-tropical climate. J Hum Nutr Diet. 1988;1(3):163-70.
169 Marks R, Foley PA, Jolley D, et al. The Effect of Regular Sunscreen Use on Vitamin D Levels in an Australian Population. Arch Dermatol. 1995;131(4):415-21. [pmid: 7726582].
170 Matsuoka LY, Wortsman J, Haddad JG, et al. Elevation of blood vitamin D2 levels does not impede the release of vitamin D3 from the skin. Metabolism. Nov. 1992;41(11):1257-60. [pmid: 1331703].
171 Reid IR, Gallagher DJ, Bosworth J. Prophylaxis against vitamin D deficiency in the elderly by regular sunlight exposure. Age Ageing. Jan. 1986;15(1):35-40. [pmid: 3953329].
172 Ho ML, Yen HC, Tsang RC, et al. Randomized study of sunshine exposure and serum 25-OHD in breast-fed infants in Beijing, China. J Pediatr. Dec. 1985;107(6):928-31. [pmid: 4067751].
173 Toss G, Andersson R, Diffey BL, et al. Oral vitamin D and ultraviolet radiation for the prevention of vitamin D deficiency in the elderly. Acta Paediatr Scand. 1982;212(3):157-61.
174 Falkenbach A, Unkelbach U, Boehm BO, et al. Bone metabolism before and after irradiation with ultraviolet light. Eur J Appl Physiol. 1993;66(1):55-9.
175 McElwain MC, Dettelbach MA, Modzelewski RA, et al. Antiproliferative effects in vitro and in vivo of 1,25-dihydroxyvitamin D-3 and a vitamin D-3 analog in a squamous cell carcinoma model system. Mol Cell Differ. 1995;3(1):31-50.
176 Ala-Houhala M. 25-Hydroxyvitamin D levels during breast-feeding with or without maternal or infantile supplementation of vitamin D. J Pediatr Gastroenterol Nutr. Apr. 1985;4(2):220-6. [pmid: 3989622].
177 Barnes MS, Robson PJ, Bonham MP, et al. Effect of vitamin D supplementation on vitamin D status and bone turnover markers in young adults. Eur J Clin Nutr. 2006;60(6):727-33. [pmid: 16391584].
178 Brazier M, Kamel S, Lorget F, et al. Biological effects of supplementation with vitamin D and calcium in postmenopausal women with low bone mass receiving alendronate. Clinical Drug Investigation. 2002;22(12):849-57.
179 Brooke OG, Brown IR, Bone CD, et al. Vitamin D supplements in pregnant Asian women: effects on calcium status and fetal growth. BMJ. Mar 15. 1980;280(6216):751-4. [pmid: 6989438]. [pmcid: 1600591].
180 Chapuy MC, Pamphile R, Paris E, et al. Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int. Mar. 2002;13(3):257-64. [pmid: 11991447].
181 Chapuy MC, Arlot ME, Duboeuf F, et al. Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med. Dec 3. 1992;327(23):1637-42. [pmid: 1331788].
182 Chan GM, Roberts CC, Folland D, et al. Growth and bone mineralization of normal breast-fed infants and the effects of lactation on maternal bone mineral status. Am J Clin Nutr. Sep. 1982;36(3):438-43. [pmid: 7113949].
183 Dawson-Hughes B, Dallal GE, Krall EA, et al. Effect of vitamin D supplementation on wintertime and overall bone loss in healthy postmenopausal women. Ann Intern Med. Oct 1. 1991;115(7):505-12. [pmid: 1883119].
184 Dawson-Hughes B, Harris SS, Krall EA, et al. Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. Sep 4. 1997;337(10):670-6. [pmid: 9278463].
185 Bischoff-Ferrari HA, Orav EJ, wson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Arch Intern Med. Feb 27. 2006;166(4):424-30. [pmid: 16505262].
186 Delvin EE, Salle BL, Glorieux FH, et al. Vitamin D supplementation during pregnancy: effect on neonatal calcium homeostasis. J Pediatr. Aug. 1986;109(2):328-34. [pmid: 3488384].
187 Deroisy R, Collette J, Albert A, et al. Comparison of the short-term effects of three oral calcium-vitamin D formulations and placebo on calcium metabolism. Current Therapeutic Research. Jun. 1998;59(6):370-8.
188 Deroisy R, Collette J, Chevallier T, et al. Effects of two 1-year calcium and vitamin D3 treatments on bone remodeling markers and femoral bone density in elderly women. Current Therapeutic Research. 1998;59(12):850-62.
189 Deroisy R, Collette J, Albert A, et al. Administration of a supplement containing both calcium and vitamin D is more effective than calcium alone to reduce secondary hyperparathyroidism in postmenopausal women with low 25(OH)vitamin D circulating levels. Aging Clin Exp Res. Feb. 2002;14(1):13-7. [pmid: 12027147].
190 Grados F, Brazier M, Kamel S, et al. Effects on bone mineral density of calcium and vitamin D supplementation in elderly women with vitamin D deficiency. Joint Bone Spine. Jun. 2003;70(3):203-8. [pmid: 12814763].
191 Brazier M, Grados F, Kamel S, et al. Clinical and laboratory safety of one year's use of a combination calcium + vitamin D tablet in ambulatory elderly women with vitamin D insufficiency: results of a multicenter, randomized, double-blind, placebo-controlled study. Clin Ther. Dec. 2005;27(12):1885-93. [pmid: 16507374].
192 Goussous R, Song L, Dallal GE, et al. Lack of effect of calcium intake on the 25-hydroxyvitamin d response to oral vitamin D3. J Clin Endocrinol Metab. Feb. 2005;90(2):707-11. [pmid: 15562015].
193 Greer FR, Searcy JE, Levin RS, et al. Bone mineral content and serum 25-hydroxyvitamin D concentration in breast-fed infants with and without supplemental vitamin D. J Pediatr. May. 1981;98(5):696-701. [pmid: 6971922].
194 Guillemant J, Le HT, Maria A, et al. Wintertime vitamin D deficiency in male adolescents: effect on parathyroid function and response to vitamin D3 supplements. Osteoporos Int. 2001;12(10):875-9. [pmid: 11716192].
195 Harris SS, Dawson-Hughes B. Plasma vitamin D and 25OHD responses of young and old men to supplementation with vitamin D3. J Am Coll Nutr. Aug. 2002;21(4):357-62. [pmid: 12166534].
196 Harris SS, Dawson-Hughes B, Perrone GA. Plasma 25-hydroxyvitamin D responses of younger and older men to three weeks of supplementation with 1800 IU/day of vitamin D. J Am Coll Nutr. Oct. 1999;18(5):470-4. [pmid: 10511329].
197 Harwood RH, Sahota O, Gaynor K, et al. A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing. Jan. 2004;33(1):45-51. [pmid: 14695863].
198 Heaney RP, Barger-Lux MJ, Dowell MS, et al. Calcium absorptive effects of vitamin D and its major metabolites. J Clin Endocrinol Metab. 1997;82(12):4111-6. [pmid: 9398723].
199 Heikkinen A, Parviainen MT, Tuppurainen MT, et al. Effects of postmenopausal hormone replacement therapy with and without vitamin D3 on circulating levels of 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D. Calcif Tissue Int. Jan. 1998;62(1):26-30. [pmid: 9405729].
200 Himmelstein S, Clemens TL, Rubin A, et al. Vitamin D supplementation in elderly nursing home residents increases 25(OH)D but not 1,25(OH)2D. Am J Clin Nutr. Oct. 1990;52(4):701-6. [pmid: 2403063].
201 Hollis BW, Wagner CL. Vitamin D requirements during lactation: high-dose maternal supplementation as therapy to prevent hypovitaminosis D for both the mother and the nursing infant. Am J Clin Nutr. Dec. 2004;80(6 Suppl):1752S-8S. [pmid: 15585800].
202 Honkanen R, Alhava E, Parviainen M, et al. The necessity and safety of calcium and vitamin D in the elderly. J Am Geriatr Soc. Aug. 1990;38(8):862-6. [pmid: 2387950].
203 Hunter D, Major P, Arden N, et al. A randomized controlled trial of vitamin D supplementation on preventing postmenopausal bone loss and modifying bone metabolism using identical twin pairs. J Bone Miner Res. Nov. 2000;15(11):2276-83. [pmid: 11092410].
204 Jensen C, Holloway L, Block G, et al. Long-term effects of nutrient intervention on markers of bone remodeling and calciotropic hormones in late-postmenopausal women. Am J Clin Nutr. Jun. 2002;75(6):1114-20. [pmid: 12036821].
205 Kenny AM, Prestwood KM, Biskup B, et al. Comparison of the effects of calcium loading with calcium citrate or calcium carbonate on bone turnover in postmenopausal women. Osteoporos Int. Apr. 2004;15(4):290-4. [pmid: 14722627].
206 Khaw KT, Scragg R, Murphy S. Single-dose cholecalciferol suppresses the winter increase in parathyroid hormone concentrations in healthy older men and women: a randomized trial. Am J Clin Nutr. May. 1994;59(5):1040-4. [pmid: 8172088].
207 Krieg MA, Jacquet AF, Bremgartner M, et al. Effect of supplementation with vitamin D3 and calcium on quantitative ultrasound of bone in elderly institutionalized women: a longitudinal study. Osteoporos Int. 1999;9(6):483-8. [pmid: 10624454].
208 Latham NK, Anderson CS, Lee A, et al. A randomized, controlled trial of quadriceps resistance exercise and vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). J Am Geriatr Soc. Mar. 2003;51(3):291-9. [pmid: 12588571].
209 Lips P, Wiersinga A, van Ginkel FC, et al. The effect of vitamin D supplementation on vitamin D status and parathyroid function in elderly subjects. J Clin Endocrinol Metab. Oct. 1988;67(4):644-50. [pmid: 3417845].
210 Lips P, Graafmans WC, Ooms ME, et al. Vitamin D supplementation and fracture incidence in elderly persons: a randomized, placebo-controlled clinical trial. Ann Intern Med. Feb 15. 1996;124(4):400-6. [pmid: 8554248].
211 Mallet E, Gugi B, Brunelle P, et al. Vitamin D supplementation in pregnancy: a controlled trial of two methods. Obstet Gynecol. Sep. 1986;68(3):300-4. [pmid: 3755517].
212 Mastaglia SR, Mautalen CA, Parisi MS, et al. Vitamin D2 dose required to rapidly increase 25OHD levels in osteoporotic women. Eur J Clin Nutr. May. 2006;60(5):681-7. [pmid: 16391587].
213 Meier C, Woitge HW, Witte K, et al. Supplementation with oral vitamin D3 and calcium during winter prevents seasonal bone loss: a randomized controlled open-label prospective trial. J Bone Miner Res. Aug. 2004;19(8):1221-30. [pmid: 15231008].
214 Nordin BE, Baker MR, Horsman A, et al. A prospective trial of the effect of vitamin D supplementation on metacarpal bone loss in elderly women. Am J Clin Nutr. Sep. 1985;42(3):470-4. [pmid: 4036849].
215 Orwoll ES, Weigel RM, Oviatt SK, et al. Calcium and cholecalciferol: effects of small supplements in normal men. Am J Clin Nutr. Jul. 1988;48(1):127-30. [pmid: 2839025].
216 Patel R, Collins D, Bullock S, et al. The effect of season and vitamin D supplementation on bone mineral density in healthy women: a double-masked crossover study. Osteoporos Int. 2001;12(4):319-25. [pmid: 11420782].
217 Pehlivan I, Hatun S, Aydogan M, et al. Maternal vitamin D deficiency and vitamin D supplementation in healthy infants. Turk J Pediatr. Oct. 2003;45(4):315-20. [pmid: 14768796].
218 Pfeifer M, Begerow B, Minne HW, et al. Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women.[erratum appears in J Bone Miner Res 2001 Oct;16(10):1935]. J Bone Miner Res. Jun. 2000;15(6):1113-8. [pmid: 10841179].
219 Riis B, Christiansen C, Rodbro P. The effect of different vitamin D treatments on serum vitamin D levels in early postmenopausal women. Acta Vitaminol Enzymol. 1984;6(2):77-82. [pmid: 6093487].
220 Rothberg AD, Pettifor JM, Cohen DF, et al. Maternal-infant vitamin D relationships during breast-feeding. J Pediatr. Oct. 1982;101(4):500-3. [pmid: 7119949].
221 Schaafsma A, Muskiet FA, Storm H, et al. Vitamin D(3) and vitamin K(1) supplementation of Dutch postmenopausal women with normal and low bone mineral densities: effects on serum 25-hydroxyvitamin D and carboxylated osteocalcin. Eur J Clin Nutr. Aug. 2000;54(8):626-31. [pmid: 10951511].
222 Sebert JL, Garabedian M, Chauvenet M, et al. Evaluation of a new solid formulation of calcium and vitamin D in institutionalized elderly subjects : a randomized comparative trial versus separate administration of both constituents. Rev Rhum Engl Ed. Apr. 1995;62(4):288-94. [pmid: 7606425].
223 Schou AJ, Heuck C, Wolthers OD. Vitamin D supplementation to healthy children does not affect serum osteocalcin or markers of type I collagen turnover. Acta Paediatr. 2003;92(7):797-801. [pmid: 12892157].
224 Sorva A, Risteli J, Risteli L, et al. Effects of vitamin D and calcium on markers of bone metabolism in geriatric patients with low serum 25-hydroxyvitamin D levels. Calcif Tissue Int. 1991;49(Suppl):S88-S89. [pmid: 1933612].
225 Sorva A, Valimaki M, Tilvis R. Effects of vitamin D and calcium supplementation in geriatric patients with low vitamin D status. Arch Gerontol Geriatr. 1991;12(Suppl. 2):481-4.
226 Sorva A, Valimaki M, Risteli J, et al. Serum ionized calcium, intact PTH and novel markers of bone turnover in bedridden elderly patients. Eur J Clin Invest. Dec. 1994;24(12):806-12. [pmid: 7705374].
227 Stephens WP, Klimiuk PS, Berry JL, et al. Annual high-dose vitamin D prophylaxis in Asian immigrants. Lancet. Nov 28. 1981;2(8257):1199-202. [pmid: 6118631].
228 Tfelt-Hansen J, Torring O. Calcium and vitamin D3 supplements in calcium and vitamin D3 sufficient early postmenopausal healthy women. Eur J Clin Nutr. Oct. 2004;58(10):1420-4. [pmid: 15114377].
229 Tjellesen L, Hummer L, Christiansen C, et al. Serum concentration of vitamin D metabolites during treatment with vitamin D2 and D3 in normal premenopausal women. Bone Miner. Oct. 1986;1(5):407-13. [pmid: 2849489].
230 Trang HM, Cole DE, Rubin LA, et al. Evidence that vitamin D3 increases serum 25-hydroxyvitamin D more efficiently than does vitamin D2. Am J Clin Nutr. Oct. 1998;68(4):854-8. [pmid: 9771862].
231 Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ. Mar 1. 2003;326(7387):469. [pmid: 12609940]. [pmcid: 150177].
232 van der Klis FR, Jonxis JH, van Doormaal JJ, et al. Changes in vitamin-D metabolites and parathyroid hormone in plasma following cholecalciferol administration to pre- and postmenopausal women in the Netherlands in early spring and to postmenopausal women in Curacao. Br J Nutr. Apr. 1996;75(4):637-46. [pmid: 8672415].
233 Vieth R, Kimball S, Hu A, et al. Randomized comparison of the effects of the vitamin D3 adequate intake versus 100 mcg (4000 IU) per day on biochemical responses and the wellbeing of patients. Nutr J. Jul. 2004;3:8. [pmid: 15260882]. [pmcid: 506781].
234 Vieth R, Chan PC, MacFarlane GD. Efficacy and safety of vitamin D3 intake exceeding the lowest observed adverse effect level. Am J Clin Nutr. Feb. 2001;73(2):288-94. [pmid: 11157326].
235 Weisman Y, Schen RJ, Eisenberg Z, et al. Single oral high-dose vitamin D3 prophylaxis in the elderly. J Am Geriatr Soc. Jul. 1986;34(7):515-8. [pmid: 3013967].
236 Zeghoud F, Ben Mekhbi H, Djeghri N, et al. Vitamin D prophylaxis during infancy: comparison of the long-term effects of three intermittent doses (15, 5, or 2.5 mg) on 25-hydroxyvitamin D concentrations. Am J Clin Nutr. Sep. 1994;60(3):393-6. [pmid: 8074071].
237 Grados F, Brazier M, Kamel S, et al. Prediction of bone mass density variation by bone remodeling markers in postmenopausal women with vitamin D insufficiency treated with calcium and vitamin D supplementation. J Clin Endocrinol Metab. Nov. 2003;88(11):5175-9. [pmid: 14602746].
238 Sato Y, Kaji M, Honda Y, et al. Abnormal calcium homeostasis in disabled stroke patients with low 25-hydroxyvitamin D. Bone. Apr. 2004;34(4):710-5. [pmid: 15050902].
239 Markestad T, Aksnes L, Ulstein M, et al. 25-Hydroxyvitamin D and 1,25-dihydroxyvitamin D of D2 and D3 origin in maternal and umbilical cord serum after vitamin D2 supplementation in human pregnancy. Am J Clin Nutr. Nov. 1984;40(5):1057-63. [pmid: 6333810].
240 Dhesi JK, Bearne LM, Moniz C, et al. Neuromuscular and psychomotor function in elderly subjects who fall and the relationship with vitamin D status. J Bone Miner Res. May. 2002;17(5):891-7. [pmid: 12009020].
241 Baeksgaard L, Andersen KP, Hyldstrup L. Calcium and vitamin D supplementation increases spinal BMD in healthy, postmenopausal women. Osteoporos Int. 1998;8(3):255-60. [pmid: 9797910].
242 Komulainen MH, Kroger H, Tuppurainen MT, et al. HRT and Vit D in prevention of non-vertebral fractures in postmenopausal women: a 5 year randomized trial. Maturitas. Nov 30. 1998;31(1):45-54. [pmid: 10091204].
243 Jackson RD, LaCroix AZ, Gass M, et al. Calcium plus vitamin D supplementation and the risk of fractures.[see comment]. N Engl J Med. Feb 16. 2006;354(7):669-83. [pmid: 16481635].
244 Porthouse J, Cockayne S, King C, et al. Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. Apr 30. 2005;330(7498):1003. [pmid: 15860827]. [pmcid: 557150].
245 Anderson FH, Smith HE, Raphael HM, et al. Effect of annual intramuscular vitamin D_3_ supplementation on fracture risk in 9440 community-living older people: the Wessex fracture prevention trial. [Abstract] ASBMR 26th Annual Meeting 2004;Presentation #1220 10/5/2004:
246 Flicker L, MacInnis RJ, Stein MS, et al. Should older people in residential care receive vitamin D to prevent falls? Results of a randomized trial. J Am Geriatr Soc. Nov. 2005;53(11):1881-8. [pmid: 16274368].
247 Law M, Withers H, Morris J, et al. Vitamin D supplementation and the prevention of fractures and falls: results of a randomised trial in elderly people in residential accommodation. Age Ageing. Sep. 2006;35(5):482-6. [pmid: 16641143].
248 Grant AM, Avenell A, Campbell MK, et al. Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. May. 2005;365(9471):1621-8. [pmid: 15885294].
249 Larsen ER, Mosekilde L, Foldspang A. Vitamin D and calcium supplementation prevents osteoporotic fractures in elderly community dwelling residents: a pragmatic population-based 3-year intervention study. J Bone Miner Res. Mar. 2004;19(3):370-8. [pmid: 15040824].
250 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. Dec. 1994;50(4):1088-101. [pmid: 7786990].
251 Graafmans WC, Lips P, Ooms ME, et al. The effect of vitamin D supplementation on the bone mineral density of the femoral neck is associated with vitamin D receptor genotype. J Bone Miner Res. Aug. 1997;12(8):1241-5. [pmid: 9258754].
252 Graafmans WC, Ooms ME, Hofstee HM, et al. Falls in the elderly: a prospective study of risk factors and risk profiles. Am J Epidemiol. Jun 1. 1996;143(11):1129-36. [pmid: 8633602].
253 Larsen ER, Mosekilde L, Foldspang A. Vitamin D and calcium supplementation prevents severe falls in elderly community-dwelling women: a pragmatic population-based 3-year intervention study. Aging Clin Exp Res. Apr. 2005;17(2):125-32. [pmid: 15977461].
254 Grant WB, Holick MF. Benefits and requirements of vitamin D for optimal health: A review. Altern Med Rev. 2005;10(2):94-111. [pmid: 15989379].
255 Holick MF. Sunlight and vitamin D for bone health and prevention of autoimmune diseases, cancers, and cardiovascular disease... Vitamin D and Health in the 21st Century: proceedings of a conference held in Bethesda, MD, October 9–10, 2003. Am J Clin Nutr. Dec. 2004;80(6S):Supplement-88S.
256 Webb RA. Who, what, where and when - influences on cutaneous vitamin D synthesis. Progress in Biophysics and Molecular Biology. 2006;92:17-25. [pmid: 16766240].
257 Diamond TH, Eisman JA, Mason RS, et al. Vitamin D and adult bone health in Australia and New Zealand: A position statement. Med J Aust. Mar 21. 2005;182(6):281-5. [pmid: 15777143].
258 Lo CW, Paris PW, Holick MF. Indian and Pakistani immigrants have the same capacity as Caucasians to produce vitamin D in response to ultraviolet irradiation. Am J Clin Nutr. Nov. 1986;44(5):683-5. [pmid: 3766454].
259 Beadle PC. The epidermal biosynthesis of cholecalciferol (vitamin D3). Photochem Photobiol. Jun. 1977;25(6):519-27. [pmid: 197552].
260 Giangiacoma J, Gleason WA Jr. 25-hydroxyvitamin D levels and rickets. Pediatrics. Nov. 1977;60(5):761. [pmid: 917648].
261 Samanek AJ, Croager EJ, Giesfor Skin Cancer PP, et al. Estimates of beneficial and harmful sun exposure times during the year for major Australian population centres. Med J Aust. Apr 3. 2006;184(7):338-41. [pmid: 16584368].
262 Webb AR, Engelsen O. Calculated ultraviolet exposure levels for a healthy vitamin D status. Photochem Photobiol. Nov. 2006;82(6):1697-703. [pmid: 16958558].
263 Kimlin MG, Olds WJ, Moore MR. Location and vitamin D synthesis: is the hypothesis validated by geophysical data?. J Photochem Photobiol B. Mar 1. 2007;86(3):234-9. [pmid: 17142054].
264 Galkin ON, Terenetskaya IP. ‘Vitamin D’ biodosimeter: basic characteristics and potential applications. J Photochem Photobiol B. Nov. 1999;53(13):12-9. [pmid: 10672524].
265 MacLaughlin JA, Anderson RR, Holick MF. Spectral character of sunlight modulates photosynthesis of previtamin D3 and its photoisomers in human skin. Science. May 28. 1982;216(4549):1001-3. [pmid: 6281884].
266 Webb AR, Kline L, Holick MF. Influence of season and latitude on the cutaneous synthesis of vitamin D3: exposure to winter sunlight in Boston and Edmonton will not promote vitamin D3 synthesis in human skin. J Clin Endocrinol Metab. Aug. 1988;67(2):373-8. [pmid: 2839537].
267 Heenen M, Giacomoni PU, Golstein P. Individual variations in the correlation between erythemal threshold, UV-induced DNA damage and sun-burn cell formation. J Photochem Photobiol B. Oct. 2001;63(13):84-7. [pmid: 11684455].
268 Armstrong BK, Kricker A. The epidemiology of UV induced skin cancer. J Photochem Photobiol B. Oct. 2001;63(13):8-18. [pmid: 11684447].
269 Gallagher RP, Lee TK. Adverse effects of ultraviolet radiation: a brief review. Prog Biophys Mol Biol. Sep. 2006;92(1):119-31. [pmid: 16580054].
270 De Fabo EC. Initial studies on an in vivo action spectrum for melanoma induction. Prog Biophys Mol Biol. Sep. 2006;92(1):97-104. [pmid: 16624384].
271 Seifert M, Rech M, Meineke V, et al. Differential biological effects of 1,25-dihydroxyVitamin D3 on melanoma cell lines in vitro. J Steroid Biochem Mol Biol. May. 2004;89–90(15):375-9.
272 Reichrath J, Rech M, Moeini M, et al. In vitro comparison of the vitamin D endocrine system in 1,25(OH)2D3-responsive and -resistant melanoma cells. Cancer Biol Ther. Jan. 2007;6(1):48-55. [pmid: 17172823].
273 Vieth R. Vitamin D supplementation, 25-hydroxyvitamin D concentrations, and safety.[see comment]. [Review] [135 refs]. Am J Clin Nutr. May. 1999;69(5):842-56. [pmid: 10232622].
274 Serhan E, Holland MR. Calcium and vitamin D supplementation failed to improve bone mineral density in Indo-Asians suffering from hypovitaminosis D and secondary hyperparathyroidism. Rheumatol Int 2005;25(4):
275 Viljakainen HT, Natri AM, Karkkainen M, et al. A positive dose-response effect of vitamin D supplementation on site-specific bone mineral augmentation in adolescent girls: a double-blinded randomized placebo-controlled 1-year intervention. J Bone Miner Res. Jun. 2006;21(6):836-44. [pmid: 16753014].
276 Papadimitropoulos E, Wells G, Shea B, et al. Meta-analyses of therapies for postmenopausal osteoporosis. VIII: Meta-analysis of the efficacy of vitamin D treatment in preventing osteoporosis in postmenopausal women. [Review] [48 refs]. Endocr Rev. Aug. 2002;23(4):560-9. [pmid: 12202471].
277 Avenell A, Gillespie WJ, Gillespie LD, et al. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database Syst Rev 2005;(3):CD000227
278 Boonen S, Laan RF, Barton IP, et al. Effect of osteoporosis treatments on risk of non-vertebral fractures: review and meta-analysis of intention-to-treat studies. Osteoporos Int. Oct. 2005;16(10):1291-8. [pmid: 15986101].
279 Gillespie LD, Gillespie WJ, Robertson MC, et al. Interventions for preventing falls in elderly people. The Cochrane Library 2006;(1):CD000340
280 Bischoff-Ferrari HA, Dawson-Hughes B, Willett WC, et al. Effect of Vitamin D on falls: a meta-analysis.[see comment]. [Review] [36 refs]. JAMA. Apr 28. 2004;291(16):1999-2006. [pmid: 15113819].
281 Broe KE, Chen TC, Weinberg J, et al. A higher dose of vitamin d reduces the risk of falls in nursing home residents: a randomized, multiple-dose study. J Am Geriatr Soc. Feb. 2007;55(2):234-9. [pmid: 17302660].
282 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-72. [pmid: 11004423].