# Executive Summary

## Introduction

The University of Ottawa Evidence-based Practice Center (UO-EPC) reviewed and synthesized the published literature on five key questions.

1 Are specific circulating concentrations of 25 hydroxyvitamin D (25(OH)D) associated with bone health outcomes in:
  A Children: rickets, bone mineral density (BMD), bone mineral content (BMC), fractures, or parathyroid hormone (PTH)?
  B Women of reproductive age (including pregnant and lactating women): BMD, calcaneal ultrasound, fractures, PTH?
  C Elderly men and postmenopausal women: BMD, fractures, falls?
2 Do food fortification, sun exposure, and/or vitamin D supplementation affect circulating concentrations of 25(OH)D?
3 What is the evidence regarding the effect of supplemental doses of vitamin D on bone mineral density and fracture or fall risk and does this vary with age groups, ethnicity, body mass index or geography?
4 Is there a level of sunlight exposure that is sufficient to maintain adequate vitamin D levels but does not increase the risk of non-melanoma or melanoma skin cancer?
5 Does intake of vitamin D above current reference intakes lead to toxicities (e.g., hypercalcemia, hypercalciuria, and calcification of soft tissue or major organs)?

Osteoporosis-related fractures constitute an important socio-economic burden. In the United States, there are 1.5 to 2 million incident fractures annually, and the direct medical costs of osteoporosis are estimated at $13.7–20.3 billion (in 2005 dollars). The burden of fractures is expected to increase over the next two decades, with an expanding aging population. Effective treatment strategies that can be implemented on a population level are needed to decrease the burden of osteoporosis.

Classical actions of vitamin D include the regulation of calcium homeostasis and the development and maintenance of the skeleton. Vitamin D's major biologic function is to maintain serum calcium and phosphorus concentrations within the normal range by enhancing intestinal absorption of calcium and release of calcium and phosphorus from bone. Low vitamin D status has been associated with the development of rickets and osteomalacia, and has been considered to lead to bone loss, fractures and falls.

Vitamin D also has non-calciotropic autocrine and paracrine functions, for example, in the regulation of cell differentiation and proliferation. The enzyme 1-alpha hydroxylase is present in many tissues in addition to the kidney, resulting in extra-renal production of 1,25-dihydroxyvitamin D. There is also emerging evidence for immunomodulatory and anti-infective properties of vitamin D.

The increased suggestions of nutritional vitamin D insufficiency in the general population and the potential impact of vitamin D status on bone health and chronic health conditions have highlighted the need to reassess current vitamin D reference intakes.

The main source of vitamin D comes from the synthesis of previtamin D_3_ from 7- dehydrocholesterol (7-DHC) in the skin through exposure to solar ultraviolet B light, at wavelengths 290–320 nm. With prolonged solar exposure, previtamin D_3_ forms inert metabolites or is changed back to 7-DHC so that toxicity from sun exposure is not a concern. Other sources of vitamin D include dietary intake from foods naturally containing vitamin D, foods fortified with vitamin D and vitamin D supplements (vitamin D_3_ or cholecalciferol, and vitamin D_2_ or ergocalciferol).

The U.S. Institute of Medicine (IOM) 1997 report on Dietary Reference Intakes for calcium and related nutrients defined circulating 25-hydroxyvitamin D as the functional indicator for vitamin D status and established dietary reference intakes for vitamin D. Circulating 25(OH)D reflects the combined contribution from cutaneous synthesis, dietary sources and vitamin D supplementation. The IOM was unable to establish estimated average requirements (EAR) on which to base recommended daily allowances (RDA) for vitamin D due to insufficient published scientific data. Adequate intakes (AI) were provided instead. An AI is expected to meet the amount needed to maintain a defined criterion of adequacy, e.g., prevention of rickets or osteomalacia, in all members of a specific healthy population.

Although the IOM identified serum 25(OH)D as the indicator for determining an adequate vitamin D intake, there is controversy on how best to define adequate vitamin D status. Assessment of vitamin D status and biochemical evidence of insufficiency have been limited by the lack of standardization of the different analytical methods used to measure 25(OH)D, including inter-assay and laboratory variability, and a lack of standard reference materials.

In addition, the tolerable upper intake level (UL) of 2,000 IU/day for individuals one year of age or older (1,000 IU in infants) was defined by the IOM based on limited evidence. The UL refers to the highest level of daily nutrient intake that is likely to pose no risk of adverse health effects to almost all individuals in the general population.

Over the last few years, a number of large randomized trials have evaluated the effect of vitamin D supplementation on fractures, falls and harms. A systematic review was conducted to synthesize the most recent evidence and address the above questions.

## Methodology

The University of Ottawa EPC developed a review team and work plan to complete this report. A technical expert panel (TEP) of content experts in vitamin D (nutrition scientists, endocrinologists, pediatricians and biochemists) was convened to help refine the key questions and to provide expertise to the team during the review process. The literature search and the synthesis of evidence were completed by the review team. The draft report was peer reviewed by members of the TEP and by external reviewers.

### Search Strategy

Using the Ovid interface, we searched the following databases: MEDLINE ® (1966 to June Week 3 2006); Embase (2002 to 2006 Week 25); CINAHL (1982 to June Week 4, 2006); AMED (1985 to June 2006); Biological Abstracts (1990 to February 2005); and The Cochrane Central Register of Controlled Trials (CENTRAL; 2nd Quarter 2006). No language restrictions were applied, and studies were restricted to human subjects.

### Eligibility Criteria

Studies for inclusion were limited, wherever possible, to randomized, controlled trials (RCTs) in order to minimize bias. Inclusion criteria for question one were broadened to include prospective cohorts, case-control and before-after studies due to the lack of studies addressing the association between serum 25(OH)D concentrations and bone health outcomes, especially in infants and children. Question four was restricted to existing systematic reviews to limit scope.

Studies that assessed vitamin D_2_ or D_3_ with or without calcium supplementation were included. We did not include randomized trials that used calcium with vitamin D as a control arm unless a placebo or lower dose vitamin D arm was also available as a comparator due to difficulty interpreting cause and effect. Vitamin D preparations, calcitriol or alphacalcidol, were not included since they are not considered nutritional supplements and have a different safety profile than vitamin D_2_ or vitamin D_3_. Studies evaluating the efficacy of vitamin D for the treatment of secondary causes of osteoporosis (e.g., glucocorticoid-induced osteoporosis, renal or liver disease) or for treatment of vitamin D-dependent rickets were not included, in an effort to minimize clinical heterogeneity and since non-dietary sources of treatment are often used as the primary treatment for some of these conditions.

### Study Selection

The results of the search were assessed using a three-step process. First, bibliographic records, including title, keywords and abstract, were screened by one reviewer. Potentially relevant records were then screened independently by two reviewers using the full text report and strict eligibility criteria. Conflicts were discussed and resolved through consensus or adjudication by a third reviewer, if needed. Relevant studies were subsequently assessed for study design and categorized by question. The reasons for exclusion were noted using a modified QUOROM format.

### Data Extraction

Two reviewers abstracted data on study and population characteristics, type of 25(OH)D assay, vitamin D intervention (type, dose, frequency), co-interventions, reported confounders or covariates and relevant bone health outcomes. One reviewer completed the primary extraction that was then verified for completeness and accuracy by a second reviewer. Differences were resolved through consensus or adjudication. Evidence tables were constructed for each of the included studies, and summary tables were prepared in order to maximize consistency in identifying pertinent data for synthesis.

### Assessment of Study Quality

An experienced reviewer assessed the quality of reporting. For the RCTs, the study quality was evaluated using the validated Jadad scale. A Jadad score of ≥ 3 (out of a possible 5) was used to indicate studies of higher quality. Allocation concealment was assessed as adequate, inadequate or unclear. For the observational studies, the methodological quality (poor, fair, good) was evaluated using the grading system adapted from Harris and colleagues.

For each section, an aggregate level of evidence (good, fair, inconsistent) was rated based on quantity, quality and consistency of results. Good evidence (e.g., for or against an association between serum 25(OH)D concentrations and a bone health outcome) was determined by consistent results across studies and at least one study of good quality. Fair evidence was evidence sufficient to determine an association but was limited by consistency of results, quantity, or quality (i.e., no studies graded as good). Inconsistent evidence was defined by an inability to make a conclusion for or against an association, in that studies had conflicting results.

### Data Synthesis

Where possible, meta-analysis of RCTs that assessed interventions, populations and outcomes (e.g., fractures or falls) was conducted using a random effects model, with an assessment of statistical heterogeneity. For continuous outcomes (e.g., serum 25(OH)D concentrations, and BMD), the difference in means between treatment groups was used for the meta-analyses. The absolute change in 25(OH)D concentrations was used for quantitative pooling. A weighted average method was used to calculate the 25(OH)D values for the combined treatment group and placebo group. The difference in means was then calculated using the weighted averages for the two combined groups. For dichotomous outcomes such as falls or fractures, RCTs were grouped by type of vitamin D supplementation and whether calcium was used as a co-intervention since we expected there might be different treatment effects with vitamin D_2_ versus D_3_, and to try to separate out the differential effects of calcium and vitamin D intake. These groupings were then used to minimize clinical heterogeneity in pooled estimates. Summary odds ratios were calculated using the number of individuals who had an event (e.g., fracture). To avoid differences in the reporting of units for 25(OH)D concentrations (i.e., nmol/L, ng/mL, μg/dL, μg/L), all values were converted to nmol/L that was the unit used for data synthesis.

## Results

The literature search identified 9,150 citations potentially relevant to the key questions and 59 studies were nominated by reviewers. We excluded 2,643 duplicates and review articles. After screening at the title and abstract level, 5,119 articles were excluded. A total of 1,447 full text articles were reviewed and of these, 682 met the inclusion criteria and were classified by study design. 515 studies were excluded on the basis of pre-set study design criteria per question whereas 167 unique studies met the criteria and were included in the evidence synthesis. There were 112 RCTs (six companion papers), 19 prospective cohorts, 30 case-control studies and six before-after studies. No systematic reviews were identified for question four.

Overall, most of the evidence on vitamin D status and bone health outcomes was in older adults (postmenopausal women and men over age 60 years), with relatively few high quality controlled studies in infants, children and adolescents. Few trials included pre-menopausal women.

While multiple studies examined the effect of vitamin D supplementation on 25(OH)D concentrations, few high quality studies examined the effect of sun exposure, the predominant source of vitamin D worldwide. Most studies were in Caucasian populations with few participants from other racial or ethnic groups.

We identified 72 studies that assessed the relationship between circulating 25(OH)D concentrations and different bone health outcomes (rickets, PTH, bone mineral content, bone mineral density, falls, fractures and performance-related measures) in different age groups.

Thirteen studies (one RCT, four before-after, eight case-control studies) of poor to fair quality assessed the association between serum 25(OH)D concentrations and established rickets, of which only one study was conducted in North America. There was fair evidence of an association between lower serum 25(OH)D concentrations and established rickets, although specific 25(OH)D concentrations were variable with mean concentrations ranging from below 30 and up to 50 nmol/L. An important confounder of the relation between vitamin D status and rickets was low dietary calcium since most studies were conducted in developing countries where calcium intake is low. Seven studies (three RCTs, four case-control studies) examined the association between serum 25(OH)D and bone health outcomes (BMC, PTH) in infants. In this age group, there was inconsistent evidence for an association between circulating 25(OH)D and bone mineral content. There was fair evidence that serum 25(OH)D concentrations were inversely associated with serum PTH at lower 25(OH)D concentrations but inconsistent evidence for a specific threshold.

Seven studies (two RCTs, three cohort studies, one before-after study, one case-control study) evaluated the relation between circulating 25(OH)D and bone health outcomes (PTH, BMC, BMD) in older children and adolescents. The two RCTs were of higher quality (Jadad score ≥ 3), and the observational studies of fair quality. There was fair evidence for an inverse association between serum 25(OH)D and PTH in older children and adolescents, with a plateau of PTH reported at 25(OH)D concentrations ranging from above 30 to 83 nmol/L. There was fair evidence of an association between serum 25(OH)D and change in BMD/BMC indices in older children and adolescents. However, the results from two RCTs of vitamin D supplementation did not confirm a consistent benefit on BMD/BMC across all sites and age groups. In addition, measures used to estimate bone mineral content and bone mineral density in children and adolescents have not been directly shown to predict fracture risk in adults.

Four studies (no RCTs, three cohort studies and one before-after study) of quality ranging from poor to good, addressed the association between serum 25(OH)D and bone health outcomes (PTH, BMD) in pregnant and/or lactating women. There was insufficient evidence for an association between circulating 25(OH)D and changes in bone mineral density during pregnancy, and fair evidence that 25(OH)D was inversely correlated with serum PTH in pregnancy. One good quality cohort did not find an association between circulating 25(OH)D and changes in BMD that occur with lactation.

In trials on food fortification, most studies used dairy products as the source of fortified food. Eleven RCTs provided the vitamin D content of the dietary source (100–1,000 IU) and were included. All trials were conducted in adults, and 6/11 trials were of higher quality. Overall, there was good evidence of a positive effect on serum 25(OH)D, although the magnitude of change varied (range 15–40 nmol/L). Combined data from two lower quality trials of food fortification at doses of 400–480 IU of vitamin D/day resulted in a mean increase of 16 nmol/L.

Eight small RCTs examined the effect of ultraviolet (UV) light exposure (four trials used sun exposure and four studies employed artificial UV-B radiation) on 25(OH)D concentrations; one trial assessed the effect of sunscreen. Seven trials enrolled Caucasian adults, and one trial enrolled Asian infants. Only two trials were of higher quality. The exact UV dose was often difficult to determine and limited synthesis of the results. There was fair evidence from randomized trials that sun exposure or artificial UV-B radiation increased serum 25(OH)D in participants with low or normal baseline serum 25(OH)D. One study in elderly Caucasian women found that exposure to one-half minimal erythemal dose (1 MED = amount of UV exposure required to induce faint erythema of the skin) three times per week for 12 weeks resulted in increases in serum 25(OH)D comparable to 400 IU vitamin D_3_ daily. It was not possible to determine the impact of effect modifiers such as age, ethnicity, body mass index or latitude from the included studies.

Seventy-four RCTs evaluated the effect of either vitamin D_3_ or D_2_ supplementation on serum 25(OH)D concentrations. Most trials were conducted in adults (57 RCTs), with few RCTs in infants (seven RCTs), children (four RCTs) and pregnant or lactating women (six RCTs). Of the 74 RCTs, 35 had quality scores ≥ 3 on the Jadad scale. Vitamin D_3_ (range 200 to 10,000 IU/day) was used in 55 RCTs, vitamin D_2_ (with dose range 400 –1800 IU/day, or single injections up to 600,000 IU) was used in 15 trials, and the type of vitamin D was not reported in four trials. In three trials of vitamin D_2_ compared to vitamin D_3_ supplementation, vitamin D_2_ appeared to have a smaller effect on serum 25(OH)D concentrations that may have been due to more rapid clearance or different metabolism. A meta-analysis of 16 trials of vitamin D_3_ was consistent with a dose-response effect on serum 25(OH)D when vitamin D_3_ doses of < 400 IU (two trials with significant increase in serum 25(OH)D of 11.36, 95% CI 8.6 –14) were compared to doses ≥ 400 IU (14 trials). However, significant heterogeneity remained after adjusting for dose. Combining results of two trials with similar populations, low baseline serum 25(OH)D and vitamin D_3_ doses (880–1,000 IU/day) resulted in a combined increase of 51 nmol/L versus control. A further exploration of the heterogeneity demonstrated a significant positive association between dose and serum 25(OH)D that was comparable to an increase of 1–2 nmol/L in 25(OH)D for every 100 additional units of vitamin D_3_. At the doses used, the relationship did not appear saturable. None of the other clinical or methodological characteristics examined (e.g., population, baseline 25(OH)D concentrations, compliance or type of 25(OH)D assay) explained the remaining heterogeneity, after adjusting for dose.

Forty-one studies (ten RCTs, 14 cohorts, 17 case-control studies) reported on the association between circulating 25(OH)D and bone health outcomes, (fractures, change in bone mineral density, falls and performance-related measures) in postmenopausal women or men over the age of 60 years. Most RCTs were of higher quality and observational studies were of fair to good quality. There was fair evidence (one RCT, three cohorts, one case-control study) of an association between lower serum 25(OH)D and an increased risk of falls in the institutionalized elderly. The evidence for an inverse association between serum 25(OH)D and risk of fractures was inconsistent across studies (three cohorts, 12 case-control studies). There was fair evidence (six RCTs, seven cohort studies and six case-control studies) for an association between serum 25(OH)D concentrations and femoral neck or total hip BMD from observational studies.

Discordance between the findings from observational studies and RCTs could be explained by the inability of observational studies to adjust for all relevant confounders such as general health status or body mass index.

Seventeen RCTs evaluated the efficacy of vitamin D_2_ or vitamin D_3_ supplementation with or without calcium on bone mineral density. Ten trials were of higher quality. Sixteen trials used vitamin D_3_ (doses 300 to 2000 IU/day), and the BMD sites most commonly assessed were lumbar spine and femoral neck. One trial included pre-menopausal women, and the rest of the trials included postmenopausal women and older men. The variability in BMD sites measured, and in the reporting of results across trials, limited synthesis. Vitamin D_3_ at doses ≥ 500 IU combined with calcium (500 – 1200 mg/day) increased BMD of the lumbar spine (four RCTs), femoral neck (three RCTs) and total body (two RCTs) relative to placebo. The Women's Health Initiative (WHI) trial found a small but significant benefit of vitamin D_3_ (400 IU) combined with 1,000 mg of calcium daily on total hip BMD in a subgroup of women who had BMD measured. Vitamin D_3_ alone (two RCTs, dose 300 or 400 IU/day) did not have a significant effect on BMD, except for an increase in BMD at the femoral neck in the trial using a dose of 400 IU.

Fifteen RCTs evaluated the effect of vitamin D on fractures in postmenopausal women and older men. Ten trials had higher quality Jadad scores of ≥ 3. Vitamin D_3_ doses ranged from 300 to 800 IU daily and for vitamin D_2_, a dose of 1,000 IU/day was used. Vertebral fractures were reported as an outcome in only three trials. Vitamin D_3_ supplementation (400 – 800 IU/day) without calcium (five trials) did not reduce the risk of fractures. Vitamin D_3_ at doses of 700 – 800 IU/day combined with calcium (500 –1200 mg/day) reduced the risk of non-vertebral fractures (seven RCTs) and hip fractures (seven RCTs). However, in a further subgroup analysis, there was fair evidence from two trials of a benefit on hip fractures in older people living in institutionalized settings (OR 0.69, 95% CI 0.53, 0.90) but the combined effect from five trials in community-dwelling elderly was not significant

Fourteen RCTs evaluated the effect of supplemental vitamin D with or without calcium on falls in postmenopausal women and older men (seven trials in community-dwelling elderly and seven trials in elderly living in institutional settings) with most trials having Jadad quality scores ≥ 3. Although there was a small overall benefit on falls (OR 0.89, 95% CI 0.80–0.99) when combining 12 trials that provided adequate data, there was inconsistent evidence across all trials. The reduction in falls was significant when six trials that adequately defined and ascertained falls were combined (OR 0.79, 95% CI 0.65–0.96). There was also a benefit on reduction in falls when combining six trials of postmenopausal women (OR 0.80, 95% CI 0.66–0.98) or combining eight RCTs of vitamin D_2_/D_3_ plus calcium supplementation vs. placebo or calcium (OR 0.84, 95% CI 0.76–0.93). Although individual trials have shown benefit of vitamin D on the incidence of falls in frail elderly institutionalized participants, in a subgroup analysis of trials on participants living in residential settings, the OR was similar to combined results of trials on community-dwelling elderly participants.

Limitations of trials reporting fractures or falls included poor compliance with vitamin D supplements, inadequate assessment of vitamin D status, methods used to ascertain falls, and losses to followup of over 20 percent, an important methodological limitation that can bias the treatment effect. Very few of the trials provided an adequate description of allocation concealment.

Higher doses of vitamin D or higher compliance rates and achievement of higher serum 25(OH)D levels, may be required to demonstrate consistent benefits on the incidence of fractures and falls. It is also possible that only specific subgroups like the frail elderly with low vitamin D status will experience a significant reduction in fractures and falls. We did not have access to individual patient data and were therefore not able to adjust for differences in patient populations between RCTs.

We did not identify any systematic reviews relevant to question four, regarding the level of sun exposure sufficient to maintain 25(OH)D concentrations but that minimizes the risk of melanoma or non-melanoma skin cancer. This highlights an area for future research. Suggested sun exposure times for vitamin D synthesis will vary with individual and environmental characteristics such as latitude and skin pigmentation (melanin).

We identified 22 RCTs that reported data on adverse events associated with vitamin D supplementation. Of these, 12 RCTs were of higher quality. Nineteen trials were conducted in adults, with only three trials in infants and children. Most of the trials were not designed to evaluate harms, were of small sample size and had short duration of exposure to vitamin D. In the adult trials, daily doses ranged from 400 to 4000 IU/day of vitamin D_3_ and 5,000 to 10,000 IU of vitamin D_2_. There was a small absolute increase in kidney stones in the WHI trial in postmenopausal women who were given 400 IU vitamin D_3_ plus 1,000 mg of calcium per day, corresponding to 5.7 events per 10,000 women years of exposure. There is fair evidence that vitamin D doses above current dietary reference intakes were well tolerated. However, most trials were not adequately powered to detect adverse events.

## Research Needs and Future Directions

Based on the results of the evidence synthesis, we identified the following vitamin D research needs:

1 Validation of laboratory assays of 25(OH)D measurement. Standard reference preparations are needed to reduce the imprecision between methods and laboratories so that serum 25(OH)D concentrations can be used to define thresholds associated with adequate vitamin D status in terms of meaningful physiological outcomes across the life cycle.
2 Consensus on endpoints of vitamin D adequacy and insufficiency. The vitamin D research community needs to reach consensus on which physiological outcomes are meaningful measures of vitamin D adequacy in infants, children, adolescents, women of reproductive age and older adults
3 Dose-response relationship of vitamin D in infants, children, pregnant and lactating women. There are few data on the effect of incremental doses of vitamin D from fortified foods and supplementation on vitamin D and calcium metabolism in infants, pregnant and lactating women, due to a lack of controlled clinical trials, and further research is needed.
4 Bone health outcome data on infants, children and adolescents. High quality randomized trials on bone health outcomes and the safety of vitamin D in infants, children and adolescents are needed to confidently determine adequate levels of intake and those levels that may pose a risk for toxicity. Additional research is needed to more accurately determine the levels of vitamin D intake required to confidently eliminate all cases of rickets in North America.
5 Consistent and clear reporting of efficacy and harms data in vitamin D trials. Consistent and clear reporting of bone health outcomes and harms across trials is needed to facilitate synthesis of the evidence in this area.
6 High quality studies in health disparity populations. High quality studies in African Americans, Hispanic Americans, Native Americans and Alaska Natives are needed to evaluate the association between specific 25(OH)D concentrations and bone health outcomes over the life span.
7 Better understanding of the modifiers of vitamin D effect. Additional research on the effect modifiers of serum 25(OH)D status such as latitude, dietary intake, age and body mass index is needed.
8 Identification of indicators of vitamin D toxicity. Sensitive and specific indices of the risk of toxicity need to be developed.
9 Review of vitamin D response and benefit-risks from UV exposure. A focused systematic review of sun exposure literature is needed to evaluate the potential benefits and harms of UV-B exposure that provides adequate vitamin D photosynthesis.