# Acknowledgments

We would like to acknowledge the guidance and expertise contributed to this project by the Technical Expert Panel members: Drs. Beth Dawson-Hughes, John Eisman, Murray Favus, Connie Weaver, Bonnie Specker, Bruce Hollis, and Frank Greer. We also thank NIH/ODS (Drs. Mary Frances Picciano, Anne Thurn, Beth Yetley and Paul Coates) and AHRQ (Drs. David Atkins, Beth Collins-Sharp and Stephanie Chang) for their guidance and input throughout the review process. The helpful comments of the peer reviewers are also gratefully acknowledged. We also thank the administrative staff of the University of Ottawa Evidence-based Practice Center (Mary Ocampo) and Helen Souci for assistance in preparation of the report, Raymond Daniel for search assistance and document acquisition and Kelli Thomas for assistance in article retrieval and table preparation. Ann Cranney acknowledges salary support from the Canadian Institutes of Health Research.