# Discussion

## Overview

A variety of study designs and age groups were included in this systematic review on the efficacy and safety of vitamin D. Since vitamin D has relevance for bone health throughout the life span, the review included assessment of infants and children, adolescents, postmenopausal women and older men. Bone health outcomes included fractures, falls, bone mineral density, bone mineral content, and serum PTH.

One of the main challenges in the vitamin D literature relates to the definition of adequate vitamin D status.^41^ Circulating concentrations of 25(OH)D reflect contributions from both cutaneous synthesis and dietary sources, making it difficult to define dietary reference intakes. A key barrier to defining thresholds of adequate vitamin D status for meaningful physiological outcomes is the imprecision of various analytical procedures to measure circulating 25(OH)D, which has been used to assess vitamin D status.

We screened a total of 9,150 records and 59 studies were reviewer nominated. A total of 1447 full text articles were reviewed and 682 met the inclusion criteria. A total of 167 studies, 112 RCTs (106 unique, six companion publications), 19 prospective cohorts (18 unique, one companion publication), 30 case-control studies and six before-after studies, were included in the evidence synthesis, with the largest body of evidence from studies in older adults.

## Question 1A. Are there Specific Concentrations of 25(OH)D Associated with Bone Health Outcomes?

### A. Children

Infants. Thirteen studies (one RCT, eight case-controls and four before-after studies of poor to fair quality) assessed the association between serum 25(OH)D concentrations and established rickets in infants and children. There is fair evidence to support an association between low serum 25(OH)D concentrations and established rickets. However, only one study (reporting on nine cases of rickets) was conducted in North America. Most studies were conducted in developing countries where calcium intake in the diet is low. Low dietary calcium can confound vitamin D status and was a major limitation of these studies. Specific 25(OH)D concentrations reported to be associated with rickets were variable with mean or median 25(OH)D concentrations ranging from below 30 to 50 nmol/L. Further studies with identical methodology (e.g., assay, doses/type of vitamin D supplementation) are required to determine a threshold of serum 25(OH)D below which the risk of rickets increases. There are no studies that tell us about serum 25(OH)D concentrations before and after treatment in rachitic cohorts of older children to adulthood (i.e., before closure of the epiphyses), not even surveys of frequency.

Seven small studies (three RCTs, and four case-control studies) examined the association between 25(OH)D concentrations and other bone health outcomes in infants. The study quality of the case-control studies was fair and two of the three RCTs had a Jadad score of ≥3/5. Outcomes included serum PTH and bone mineral content (BMC). There is insufficient evidence of an association between serum 25(OH)D concentrations and BMC across studies. There is fair evidence that 25(OH)D concentrations are inversely associated with serum PTH but inconsistent evidence for a specific threshold of 25(OH)D.

Older Children and Adolescents. Seven studies (two RCTs, three prospective cohorts, one case-control and one before-after study) examined specific circulating concentrations of 25(OH)D and the association with bone health outcomes (PTH, BMD and BMC) in older children and adolescents. No studies reported fractures as an outcome. The study quality was high for the two RCTs and was fair for the observational studies.

There is fair evidence for an inverse relationship between serum 25(OH)D concentrations and serum PTH in older children and adolescents, with a plateau of PTH at serum 25(OH)D levels ranging from above 30 to 83 nmol/L. There is fair evidence that circulating 25(OH)D levels are associated with change in BMD/BMC from studies in older children and adolescents. Results from two RCTs did not confirm a consistent benefit of vitamin D supplementation across all BMD sites.

A study published after our search by Viljakainen in 228 adolescent girls used two doses of vitamin D_3_ (200 and 400 IU daily) and reported that positive effects on BMC were seen at a serum 25(OH)D concentration of > 50 nmol/L.^275^

The measures used to assess bone mineral (BMC/BMD) in older children and adolescents have not been directly shown to predict bone health outcomes in adulthood.

### B. Pregnant and Lactating Women

Four observational studies (three prospective cohorts and one before-after study), addressed the association between serum 25(OH)D concentrations and bone health outcomes (PTH, BMD) in pregnant or lactating women. The quality of studies ranged from poor to good. There is good evidence from one cohort that there was no association between serum 25(OH)D and the bone mineral density changes that occur during lactation. Limitations include the small number of studies, and that all relevant confounders were not assessed in the included studies.

### C. Postmenopausal Women and Elderly Men

There were 41 studies (10 RCTs, 14 prospective cohorts, and 17 case-control studies) that assessed serum 25(OH)D and bone health outcomes in postmenopausal women and elderly men.

Fifteen observational studies (ranging from poor to fair quality) reported on the association between serum 25(OH)D concentrations and fractures. There is inconsistent evidence to support an association between serum 25(OH)D concentrations and an increased risk of fracture. Five studies of good quality evaluated the association between serum 25(OH)D and falls. There is fair evidence mainly from observational studies that low serum 25(OH)D concentrations are associated with an increased risk of falls in elderly populations in residential settings. Seven studies of fair to good quality assessed the relation between serum 25(OH)D and different fall-related performance measures. There is inconsistent evidence for an association between serum 25(OH)D concentrations and performance measures. Nineteen studies assessed the association between serum 25(OH)D concentrations and BMD, and there is fair evidence from observational studies for an association between serum 25(OH)D concentrations and changes in hip BMD sites. Some studies identified specific serum concentrations of 25(OH)D below which falls, fractures or bone loss increased; these values ranged from around 40 to 80 nmol/L.

## Question 2A. Does Dietary Intake from Foods Fortified with Vitamin D Affect Concentrations of Circulating 25(OH)D?

Eleven of the thirteen identified trials on food fortification and circulating 25(OH)D provided the vitamin D content (200 – 1,000 IU) of the dietary source. Most trials used dairy products as the source of fortified foods. Six of 11 trials had Jadad quality scores ≥3. Meta-analysis of the trials was limited due to the heterogeneity of treatment effect. Food fortification with vitamin D resulted in significant increases in serum 25(OH)D concentrations with the treatment effect ranging from 15 to 40 nmol/L. The combined effect of fortified food from two trials with vitamin D_3_ doses equivalent to 400–480 IU was 16 nmol/L (95% CI 12.9, 18.5). It was not possible from these trials to determine if the effect of food fortified with vitamin D on serum 25(OH)D concentrations varied by age, BMI or ethnicity.

## Question 2B. What is the Effect from UV Exposure on Circulating 25(OH)D Concentrations? Does This Vary With Different Age Groups, Ethnicity, Use of Sunscreen, Latitude and/or BMI?

Eight small, randomized trials of ultraviolet-B radiation (sun exposure or artificial light) were identified and reviewed qualitatively. Heterogeneity with respect to age, area of skin exposure, dose and reporting of outcomes limited the synthesis of results. Most trials had low quality scores and were short in duration. All but one trial was conducted in adults. UV-B exposure (natural or artificial) increased serum 25(OH)D in vitamin D deficient and sufficient subjects, with mean increases ranging from 15 to 42 nmol/L. The trials used variable methods to assess the vitamin D synthetic capacity of both natural and artificial sources of UV exposure. In contrast to the large number of vitamin D supplementation RCTs that assessed 25(OH)D levels, there was a lack of high quality RCTs on the effect of UV exposure on 25(OH)D concentrations. An objective measurement of skin pigmentation was not used in the trials. It was not possible from these trials to determine if serum 25(OH)D results varied by age, ethnicity, skin pigmentation type, BMI or latitude. Further research needs to clarify the exact doses needed to maintain 25(OH)D concentrations over time, in the absence of supplementation.

## Question 2C. What Is the Effect of Vitamin D Supplementation on Concentrations of Circulating 25(OH)D?

Seventy-four trials evaluated the effect of either vitamin D_3_ or D_2_ supplementation on serum 25(OH)D concentrations. Eight trials were in infants, five in pregnant or lactating women, four in older children or adolescents, 10 in younger adults and 47 in postmenopausal women or older men. Thirty-four of the trials had quality scores of ≥ 3. The majority of the trials used vitamin D_3_ (with or without calcium) and 15 trials used vitamin D_2_ preparations. Twenty-four trials were conducted in vitamin D deficient populations.

Vitamin D_2_ was used in four of seven infant trials and the study quality of the infant trials was low. The evidence suggests that 400 IU of vitamin D_2_ is required for breast-fed infants and perhaps even higher doses for infants who are at risk of vitamin D deficiency (northern latitudes, born at end of winter). Three trials that used vitamin D_2_ (100 to 1000 IU) had mean increases in serum 25(OH)D ranging from 3–50 nmol/L. There was a paucity of trials that used vitamin D_3_ in infants.

There were six low quality small trials in pregnant or lactating women with either vitamin D_2_ or D_3_ as the intervention. Vitamin D supplementation of 1000–1600 IU/day was effective in normalizing vitamin D levels to the reference range in most pregnant and lactating women.

In adults, a range of vitamin D doses was used (200 – 10,000 IU/day). Three trials in healthy adults that compared vitamin D_2_ to vitamin D_3_ found smaller increases over time in serum 25(OH)D concentrations with vitamin D_2_, and this may be secondary to more rapid clearance or different metabolism of the D_2_ isoform.^61^ Most trials did not explore the role of effect modifiers such as body mass index. Meta-analysis of 16 trials (vitamin D_3_ with or without calcium) was consistent with a dose-response relationship although the heterogeneity was very high. Subgroup and sensitivity analyses did not sufficiently explain the study heterogeneity except when combining two trials using doses less than 400 IU daily (weighted mean difference of 11.36). An exploratory analysis of heterogeneity using dose demonstrated a significant association between dose and serum 25(OH)D levels, the results comparable to an increase of 1 – 2 nmol/L in serum 25(OH)D concentrations for every 100 IU of vitamin D_3._

## Question 3. What is the Evidence Regarding the Effect of Supplemental Vitamin D on Bone Density, Fractures and Falls in Postmenopausal Women and Elderly Men?

Seventeen RCTs evaluated the effect of vitamin D_2_ or D_3_ supplementation with or without calcium supplementation on bone mineral density, and thirteen trials scored ≥ 3 on the Jadad score, consistent with higher quality. A combination of vitamin D_3_ plus calcium maintained or resulted in small increases in BMD at the lumbar spine, femoral neck and total hip relative to placebo. Previous systematic reviews have noted similar results of the effect of vitamin D on BMD.^276^ Limitations of BMD measurement include that it is a surrogate measure for fractures, and that it does not distinguish between bone mass and the degree of mineralization, which is of relevance in vitamin D deficiency.

Fifteen RCTs evaluated the effect of vitamin D_2_ or D_3_ (with or without calcium supplementation) on fractures in postmenopausal women and elderly men. The majority of the trials used vitamin D_3_ preparations (300 – 800 IU daily). Ten trials were of higher quality although high losses to followup and inadequate reporting of allocation concealment were limitations of a number of trials. Vertebral fractures were not included as an outcome in most trials. Vitamin D_3_ (700 – 800 IU daily) combined with calcium supplements (500 – 1200 mg) significantly reduced non-vertebral and hip fractures although the benefit was predominantly in elderly subjects living in institutionalized settings (hip fractures, OR 0.69, 95% CI 0.53–0.90). The benefit of vitamin D and calcium on fractures in community-dwelling individuals was inconsistent across trials. Our results differ from some meta-analyses,^216,^ ^276^ which may be related to differences in eligibility criteria. Other reviews have included trials of active vitamin D analogues.^276,^ ^277^ In addition, our systematic review included two large trials^244,^ ^248^ published since 2004, and these trials did not show benefit of vitamin D_3_ on fractures. Our results are similar to a 2005 Cochrane review^277^ and another recently updated meta-analysis.^278^

Fourteen RCTs evaluated the effect of vitamin D on the risk of falls in older adults. Eleven trials had higher quality scores. The combined results of 12 trials using oral vitamin D did not demonstrate a significant reduction in fall risk. An analysis of six trials that adequately ascertained falls is consistent with a significant effect of vitamin D on falls (OR 0.79, 95% CI 0.65–0.96). Subgroup analyses showed a significant reduction in falls upon combining trials of postmenopausal women only. Our results are similar to another meta-analysis.^279^

In a previous meta-analysis, Bischoff-Ferrari concluded that vitamin D should reduce an older person's risk of falling by 22 percent. However, two out of five included trials used active vitamin D analogues, and women taking these had the largest reduction in falls.^280^ An RCT by Flicker (2005) that is included in our review was one of the first trials of vitamin D_2_ supplementation (1,000 IU) that found a significant reduction in falls in older individuals living in residential care.^246^ Since our search, a five month randomized placebo-controlled trial of vitamin D_2_ (200, 400, 600 and 800 IU per day) on falls in an elderly nursing home population was published. In this dose-finding trial, 800 IU of vitamin D_2_ per day was associated with a reduced risk of falls compared to placebo.^281^

Limitations of the fracture and falls trials included suboptimal compliance with vitamin D, inadequate assessment of vitamin D status of the study populations and large losses to followup.

In some cases, the RCT evidence is discordant with findings from the observational studies. For example, prospective cohort studies reported that lower serum 25(OH)D concentrations were associated with an increased risk of falls in institutionalized populations. In contrast, combined trials of elderly in residential settings did not demonstrate a significant benefit of vitamin D supplementation although individual trials have demonstrated a benefit. The discrepancy between the observational studies and the combined RCTs could be explained by the failure of observational studies to adjust for all relevant confounders, such as level of mobility or general health status. The method of ascertainment was a limitation of some of the RCTs.

## Question 4. Is There a Level of Sunlight Exposure That Is Sufficient to Maintain Adequate Vitamin D Concentrations, But Does Not Increase the Risk of Skin Cancer?

We did not retrieve any systematic reviews in our literature search that addressed this question. Our search strategy may not have identified studies in the dermatology or cancer literature that evaluated the effect of UV exposure in terms of minimal erythemal dose (MED) on risk of skin cancer. An ecological study in Australia by Samanek et al. used daily ultraviolet index data to derive sun exposure times (1/6 - 1/3 MED) for fair-skinned people based on current reference vitamin D intakes. Solar exposure times for 15 percent of the body surface at noon in summer were short and varied from 2–10 minutes depending on the latitude. The authors stated that it is impractical to provide a uniform message to the general population given the number of individual and environmental variables that need to be taken into consideration (e.g., latitude, time of day, skin pigmentation).^261^ A recently published study used a vitamin D action spectrum and U.S. reference conditions to calculate UV exposure times comparable to 1,000 IU vitamin D.^262^

## Question 5. Does Intake of Vitamin D, Above Current Reference Intakes, Lead to Toxicity?

Twenty-two randomized trials provided data on toxicity outcomes although no trials reported data on soft tissue calcification. Twenty-one of the trials used doses of vitamin D above current reference intakes. Most of the trials were conducted in older adult populations and used vitamin D_3_ preparations. Twelve trials had scores ≥ 3 on the Jadad scale. One trial in infants with 600,000 IU vitamin D_3_ (one dose) reported an increased risk of hypercalcemia. Most trials were small, of short duration and inadequately powered to assess adverse events.

Overall, vitamin D above current reference intakes was generally well tolerated. There was a non-significant increase in the risk of hypercalcemia and hypercalciuria with vitamin D relative to placebo, and these events did not appear clinically significant. We were unable to determine if there were differences between vitamin D_2_ and D_3_. The only significantly increased adverse event identified was an increase in renal stones in the large seven year WHI trial in women 50 to 79 years of age who were taking 400 IU of vitamin D_3_ (the current reference intake for participants aged 50 to 70 years, and lower than the reference intake of 600 IU for participants > 70 years) plus 1000 mg calcium although the calcium intake of this cohort was higher than seen in the general population: Hazard Ratio 1.17 (95% CI 1.02, 1.34), corresponding to 5.7 events per 10,000 person years of exposure. Most studies excluded patients with a known history of hypercalcemia or renal stones so results may not be generalizable to the overall population. Limitations of the evidence include the incomplete reporting of outcomes, variable exposure lengths, small sample sizes and the lack of long-term data on harms associated with higher intakes.

## Strengths and Limitations of the Review

Due the large body of evidence and after consulting with the TEP, AHRQ and ODS, we limited our review to RCTs wherever possible since most grading systems place RCTs at the top of the evidence hierarchy. We included observational studies if there was a lack of RCTs to address the question, as in the case of question one. For question four, to limit scope, we had restricted study type to existing systematic reviews but were unable to identify reviews relevant to this question. This evidence report includes English language publications only. However, previous research indicates that limiting reviews to English language publications is unlikely to bias the overall results.^282^

For the meta-analyses, we did not have individual patient data and so were unable to adjust for baseline differences between trials such as baseline vitamin D status or level of dietary intake. The decision to combine studies was based on clinically relevant groupings (e.g., vitamin D type (D_3_ versus D_2_), whether or not vitamin D was combined with calcium, route of administration).

Our review has a number of strengths, including a structured and thorough search of electronic databases and reviewer nomination of relevant literature. All screening for our review was done in duplicate for consensus and data extraction was completed by one reviewer and then checked by a second reviewer.

Other limitations relate to the methodological quality of the original studies (e.g., loss to followup, inadequate reporting of allocation concealment), the lack of details on the exact amount of vitamin D in supplements in most trials and the failure to explore the effect of relevant covariates.

## Conclusions and Knowledge Gaps

The evidence base in older adults was much larger than the available evidence in infants, children and adolescents. In addition, there was a lack of studies in perimenopausal women and early postmenopausal women. The specific concentration of 25(OH)D associated with vitamin D-deficient rickets in infants and young children is uncertain, given the paucity of studies in North American populations, and the imprecision and inaccuracy of the assays used to assess serum 25(OH)D.

There was inconsistent evidence for an association between serum 25(OH)D levels and bone mineral content in infants, and fair evidence for an association between 25(OH)D and changes in BMC/BMD (total body, lumbar spine) in adolescents. It should be noted that the measures used to estimate bone mineral (BMC/BMD) in infants, children and adolescents have not been directly shown to predict bone health outcomes in adulthood.

Vitamin D status in pregnancy varies with ethnicity and women at risk include non-whites living at all latitudes. Changes in serum 25(OH)D concentrations during lactation were not associated with changes in BMD. There is a lack of research on the association between vitamin D status in pregnancy and bone health outcomes in both the mother and offspring. There is also a lack of studies in premenopausal women.

In observational studies of postmenopausal women and elderly men, low serum 25(OH)D concentrations were associated with bone loss at hip sites, and increased fall and fracture risk. The overall level of evidence varied from fair (falls and bone mineral density) to inconsistent (fractures and performance measures). Vitamin D fortified foods consistently increased serum 25(OH)D levels in younger and older adults. Ultraviolet-B exposure increased serum 25(OH)D concentrations in both vitamin D deficient and sufficient subjects across age groups but due to heterogeneity of populations and dose, it was difficult to determine the exact amount of UV-B radiation required to attain specific serum 25(OH)D concentrations and how this will vary with skin type and latitude.

Numerous trials have evaluated the effect of vitamin D supplementation on serum 25(OH)D concentrations, although these trials were mostly in adult populations. Vitamin D_2_ and D_3_ may have differential effects on serum 25(OH)D concentrations with vitamin D_2_ having enhanced clearance and/or different metabolism.

The combination of vitamin D_3_ plus calcium increases bone mineral density in older adults. Consistent with an effect of vitamin D_3_ plus calcium on BMD in postmenopausal women and older men, vitamin D_3_ at doses of 800 IU/day with calcium reduce the risk of fractures in the institutionalized elderly. The results from trials in community-dwelling older participants are inconsistent, although there may be a positive effect of vitamin D_3_ with calcium on reduction of hip fractures in older community-dwelling women who are compliant with vitamin D. A potential explanation for the lack of a consistent benefit of vitamin D on fractures and falls in all trials is that attained serum 25(OH)D levels were not high enough and that compliance with vitamin D supplementation was inadequate. The incomplete ascertainment of vitamin D status in a number of trials limited our ability to explore the effect of baseline and attained 25(OH)D levels on fall and fracture risk.

We did not retrieve any reviews relevant to question four, regarding the level of sun exposure sufficient to maintain 25(OH)D concentrations but that minimizes the risk of non-melanoma or melanoma skin cancer. This highlights an area for future research. Recommended sun exposure times will vary by differences in individual and environmental characteristics, e.g., skin pigmentation (melanin) and latitude.

Data on harms were not consistently reported in the trials, and most trials were not adequately powered to assess harms. The effect of vitamin D supplementation above current reference levels was not reported to be associated with clinically significant adverse events. An increased risk of kidney stones with vitamin D_3_ (400 IU, the daily reference intake for trial participants aged 50 to 70 years, and below the reference intake for participants > 70 years) plus calcium was reported in the WHI trial.

## Research Needs and Future Directions

Based on the results of the evidence synthesis, we identified the following vitamin D research needs:

1 Validation of laboratory assays of 25(OH)D measurement. Standard reference preparations are needed to reduce the imprecision between methods and laboratories so that serum 25(OH)D concentrations can be used to define thresholds associated with adequate vitamin D status in terms of meaningful physiological outcomes across the life cycle.
2 Consensus on endpoints of vitamin D adequacy and insufficiency.The vitamin D research community needs to reach consensus on which physiological outcomes are meaningful measures of vitamin D adequacy in infants, children, adolescents, women of reproductive age and older adults.
3 Dose-response relationship of vitamin D in infants, children, pregnant and lactating women. There are few data on the effect of incremental doses of vitamin D from fortified foods and supplementation on vitamin D and calcium metabolism in infants, pregnant and lactating women, due to a lack of controlled clinical trials, and further research is needed.
4 Bone health outcome data on infants, children and adolescents. High quality randomized trials on bone health outcomes and the safety of vitamin D in infants, children and adolescents are needed to confidently determine adequate levels of intake and those levels that may pose a risk for toxicity. Additional research is needed to more accurately determine the levels of vitamin D intake required to confidently eliminate all cases of rickets in North America.
5 Consistent and clear reporting of efficacy and harms data in vitamin D trials. Consistent and clear reporting of bone health outcomes and harms across trials is needed to facilitate synthesis of the evidence in this area.
6 High quality studies in health disparity populations. High quality studies in African Americans, Hispanic Americans, Native Americans and Alaska Natives are needed to evaluate the association between specific 25(OH)D concentrations and bone health outcomes over the life span.
7 Better understanding of the modifiers of vitamin D effect. Additional research on the effect modifiers of 25(OH)D status such as latitude, dietary intake, age and body mass index is needed.
8 Identification of indicators of vitamin D toxicity. Sensitive and specific indices of the risk of toxicity need to be developed.
9 Review of vitamin D response and benefit- risks from UV exposure. A focused systematic review of sun exposure literature is needed to evaluate potential benefits and harms of UV-B exposure that provides adequate vitamin D photosynthesis.