# Appendix I. List of Excluded Studies at Full-Text Screening (Level 2 screening)

## References

Design of the Women's Health Initiative clinical trial and observational study. The Women's Health Initiative Study Group. Control Clin Trials 1998;19(1):61–109. Does not meet criteria for eligibility.
Hazards of overuse of vitamin D. Am J Clin Nutr 1975;28(5):512–513. Does not meet criteria for eligibility.
Rickets in the premature baby. Br Med J 1971;3(768):205. Does not meet criteria for eligibility.
25-hydroxycholecalciferol. JAMA 1970;213(9):1480–1481. Does not meet criteria for eligibility.
Vitamin D. S Afr Med J 1967;Suid-Afrikaanse Tydskrif Vir Geneeskunde. 41(23):565–566. Does not meet criteria for eligibility.
Vitamin D may prevent falls. Med Today 2004;5(7):8–9. Not obtainable at time of submission.
Vitamin D reduces risk of falls. Geriatrics and Aging 2004;7(6):Not obtainable at time of submission.
Vitamin D: Cheap and viable primary prevention of fractures. Geriatrics and Aging 2003;6(4):11. Does not meet criteria for eligibility.
Secondary prevention of hip fractures should be standard care for patients who sustain a hip fracture. Drugs & Therapy Perspectives 2003;19(1):14–17. Does not meet criteria for eligibility.
Underutilization of calcium and vitamin D supplements in an academic long-term care facility. J Am Med Dir Assoc 2004;5(2):98–100. Does not meet criteria for eligibility.
Cost-effectiveness of hip protectors in the prevention of osteoporosis related hip fractures in elderly nursing home residents. Br J Rheumatol 2004;31(8):1607–1613. Does not meet criteria for eligibility.
Review: prophylactic use of vitamin D reduced falls in older people. Evid Based Nurs 2004;7(4):119. Does not meet criteria for eligibility.
Vitamin D and falls in the elderly. Bandolier 2004;11(7):7. Does not meet criteria for eligibility.
Resistance exercises or vitamin D did not improve physical health or reduce falls in frail older people. Evid Based Nurs 2003;6(4):116–117. Does not meet criteria for eligibility.
Oral vitamin D3 supplementation reduced fractures in community dwelling elderly people. Evid Based Nurs 2003;6(4):113. Does not meet criteria for eligibility.
Evidence for practice. Effect of vitamin D3 supplementation. AORN J 2003;78(5):852, 854. Does not meet criteria for eligibility.
Bonafide advice: smart choices in childhood can lay the foundation for strong bones to last a lifetime. USC Health 2003;10(4):20–23. Does not meet criteria for eligibility.
Can vitamin D prevent fractures in men and women?. Evidence-Based Practice 2003;6(6):4, 2p. Does not meet criteria for eligibility.
Lessons to be learned: a case study approach. Sunshine-induced hypercalcaemia?. Journal of the Royal Society for the Promotion of Health 2002;122(3):194–196. Does not meet criteria for eligibility.
Vitamin D helps to prevent hip fractures in elderly women. Alternative & Complementary Therapies 2003;9(2):52. Does not meet criteria for eligibility.
Research and professional briefs. Intake of calcium and vitamin D in 3 Canadian long-term care facilities. J Am Diet Assoc 2002;102(2):244–247. Does not meet criteria for eligibility.
Positive effects of anabolic steroids, vitamin D and calcium on muscle mass, bone mineral density and clinical function after a hip fracture: a randomised study of 63 women. Journal of Bone and Joint Surgery (British) 2002;84B(4):497–503. Does not meet criteria for eligibility.
Therapeutics in osteoporosis: a case study. Journal of Orthopaedic Nursing 2002;6(1):30–34. Does not meet criteria for eligibility.
Research briefings. Boston University School of Medicine: researchers report vitamin D intoxification from supplements. On Call 2001;4(7):10. Does not meet criteria for eligibility.
Does parathyroid hormone use safely reduce the risk of fracture in women with osteoporosis?. commentary on Neer RM, Arnaud CD, Zanchetta JR et al. Effect of parathyroid hormone (1–34) on fractures and bone mineral density in postmenopausal women with osteoporosis. N ENGL J MED 2001;344:1434–41. Evidence-Based Practice 2001;4(8):3, insert. Does not meet criteria for eligibility.
Preventing falls and subsequent injury in older people. Qual Health Care 1996;5(4):243–249. Does not meet criteria for eligibility.
The A, B, C's of bone building in adolescence. J Am Acad Nurse Pract 2000;12(4):135–140. Does not meet criteria for eligibility.
Calcium and vitamin D reduced non-vertebral fractures and bone loss in the elderly [commentary on Dawson-Hughes B, Harris SS, Krall EA, et al. Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. NEW ENGL J MED 1997 Sep 4;337:670–6]. Evid Based Nurs 1998;1(2):48. Does not meet criteria for eligibility.
Bone loss and vitamin D intoxication. Nurses' Drug Alert 1997;21(9):70–71. Does not meet criteria for eligibility.
Commentary on Vitamin D3 and calcium to prevent hip fractures in elderly women [original article by Chapuy M et al appears in NEW ENGL J MED 1992;327(23):1637–42].
AWHONN's Women's Health Nursing Scan 1993;7(3):5. Not obtainable at time of submission.
Vitamin D3 plus calcium to prevent fractures. Nurses' Drug Alert 1993;17(2):10. Does not meet criteria for eligibility.
WHO calls for adequate vitamin D supplementation. Can Pharm J 2005;. 275(7357):09. Does not meet criteria for eligibility.
Vitamin D deficiency common in postmenopausal women. Geriatrics and Aging 2005;8(10):11. Does not meet criteria for eligibility.
Prevalence of vitamin D inadequacy among postmenopausal north American women receiving osteoporosis therapy. Obstet Gynecol Surv 2005;60(10):658–659. Does not meet criteria for eligibility.
Calcium/vitamin D not effective for secondary prevention of fracture. J Fam Pract 2005;54(8):658–662. Does not meet criteria for eligibility.
Calcium and vitamin D supplements offer modest improvements in bone and greater benefits with faithful adherence. Nutr Today 2006;41(2):87. Does not meet criteria for eligibility.
Vitamin D: the bone builder. Johns Hopkins Medical Letter, Health After 50 2006;17(12):7. Does not meet criteria for eligibility.
In brief. Nurs Times 2006;102(8):8. Does not meet criteria for eligibility.
Bad bones. Nutrition Action Healthletter 2005;32(5):12. Does not meet criteria for eligibility.
Drugs and herbs. Calcium and vitamin D: beyond the bones. Consum Rep Health 2005;17(9):7. Does not meet criteria for eligibility.
Are you getting enough vitamin D to fight fractures? Analysis shows older adults need more than the RDA to build bone health. Tufts University Health & Nutrition Letter 2005;23(10):1–2. Does not meet criteria for eligibility.
New horizons for vitamin D. Tufts University Health & Nutrition Letter 2004;22(5):3. Does not meet criteria for eligibility.
Clinical highlights. Do vitamin D and calcium curb fractures in the elderly?. RN 2005;68(10):18. Does not meet criteria for eligibility.
Doubt over ability of calcium and vitamin D to prevent fractures. Practice Nurse 2005;29(9):6. Does not meet criteria for eligibility.
Breaking up: strong bones need more than calcium. Nutrition Action Healthletter 2005;32(3):3–8. Does not meet criteria for eligibility.
Vitamin D's muscle-strengthening effect and fracture prevention. HealthFacts 2004;29(6):6. Does not meet criteria for eligibility.
Osteoporosis. Obstet Gynecol 2004;104(4):Supplement-76S. Does not meet criteria for eligibility.
Aarskog D, Aksnes L, Markestad T. Effect of parathyroid hormone on vitamin D metabolism in osteopetrosis. Pediatrics. 1981;68(1):109-112. Does not meet criteria for eligibility. [pmid: 6264377].
Abrahamsen B, Madsen JS, Tofteng CL, et al. A common methylenetetrahydrofolate reductase (C677T) polymorphism is associated with low bone mineral density and increased fracture incidence after menopause: Longitudinal data from the Danish osteoporosis prevention study. Journal of Bone & Mineral Research. 2003;18(4):723-729. Does not meet criteria for eligibility. [pmid: 12674333].
Adams ND, Gray RW, Lemann J. The calciuria of increased fixed acid production in humans: evidence against a role for parathyroid hormone and 1,25(OH)2-vitamin D. Calcif Tissue Int. 1979;28(3):233-238. Does not meet criteria for eligibility. [pmid: 228816].
Akashi S, Motizuki H. Screening for hypercalciuria. Nippon Shonika Gakkai Zasshi. 1990;32(6):701-709. Does not meet criteria for eligibility.
Aksoy S, Abali H, Dincer M, et al. Hypocalcemic effect of zoledronic acid or other bisphosphonates may contribute to their antiangiogenic properties.[see comment]. Med Hypotheses. 2004;62(6):942-944. Does not meet criteria for eligibility. [pmid: 15142653].
Al Ali H, Fuleihan GE. Nutritional osteomalacia: substantial clinical improvement and gain in bone density posttherapy. J Clin Densitom. 2000;3(1):97-101. Does not meet criteria for eligibility. [pmid: 10745306].
Al Maatouq MA, El Desouki MI, Othman SA, et al. Prevalence of osteoporosis among postmenopausal females with diabetes mellitus. Saudi Med J. 2004;25(10):1423-1427. Not obtainable at time of submission. [pmid: 15494815].
Al Qadreh A, Schulpis KH, Athanasopoulou H, et al. Bone mineral status in children with phenylketonuria under treatment. Acta Paediatr. 1998;87(11):1162-1166. Does not meet criteria for eligibility. [pmid: 9846918].
Alekel DL, Mortillaro E, Hussain EA, et al. Lifestyle and biologic contributors to proximal femur bone mineral density and hip axis length in two distinct ethnic groups of premenopausal women. Osteoporos Int. 1999;9(4):327-338. Does not meet criteria for eligibility. [pmid: 10550450].
Alfaham M, Woodhead S, Pask G, et al. Vitamin D deficiency: a concern in pregnant Asian women. Br J Nutr. 1995;73(6):881-887. Does not meet criteria for eligibility. [pmid: 7632669].
Ali MY, Gopal KV, Llerena LA, et al. Hypercalcemia associated with infection by Cryptococcus neoformans and Coccidioides immitis. Am J Med Sci. 1999;318(6):419-423. Does not meet criteria for eligibility. [pmid: 10616168].
Allen SH, Shah JH. Calcinosis and metastatic calcification due to vitamin D intoxication. A case report and review. [Review] [49 refs]. Horm Res. 1992;37(12):68-77. Does not meet criteria for eligibility. [pmid: 1398478].
Aloia JF. Role of calcitriol in the treatment of postmenopausal osteoporosis. Metabolism: Clinical & Experimental. 1990;39(4 Suppl 1):35-38. Does not meet criteria for eligibility. [pmid: 2182976].
Aloia JF, Miele G, Culleton J, et al. Treatment of osteoporosis with salmon calcitonin clinical experience with 100 patients. Adv Ther. 1991;8(1):36-47. Does not meet criteria for eligibility.
Aloia JF, Mikhail M, Pagan CD, et al. Biochemical and hormonal variables in black and white women matched for age and weight.[see comment]. Journal of Laboratory & Clinical Medicine. 1998;132(5):383-389. Does not meet criteria for eligibility. [pmid: 9823932].
Alon U, Berkowitz D, Berant M. Idiopathic infantile hypercalcemia: rapid response to treatment with calcitonin. Child Nephrology & Urology. 1992;12(1):47-50. Does not meet criteria for eligibility. [pmid: 1606583].
Alper BS. Evidence-based medicine. Efficacy of calcium and vitamin D for fracture prevention questioned. Clinical Advisor. 2005;8(7):94-95. Does not meet criteria for eligibility.
Anatoliotaki M, Tsilimigaki A, Tsekoura T, et al. Congenital rickets due to maternal vitamin D deficiency in a sunny island of Greece. Acta Paediatr. 2003;92(3):389-391. Does not meet criteria for eligibility. [pmid: 12725557].
Anderson F. Vitamin D for older people: How much, for whom and - Above all - Why?. Age & Ageing. 2005;34(5):425-426. Does not meet criteria for eligibility. [pmid: 16107448].
Antoniucci DM, Vittinghoff E, Blackwell T, et al. Vitamin D insufficiency. Does not affect bone mineral density response to raloxifene. J Clin Endocrinol Metab. 2005;90(8):4566-4572. Does not meet criteria for eligibility. [pmid: 15899959].
Apostolou T, Tziamalis M, Christodoulidou C, et al. Regression of massive tumoral calcinosis of the ischium in a dialysis patient after treatment with reduced calcium dialysate and i.v. administration. Clin Nephrol. 1998;50(4):247-251. Does not meet criteria for eligibility. [pmid: 9799070].
Ardawi M, Salleh Nasrat, Hassan AN, et al. Vitamin D status and calcium-regulating hormones in Saudis: A prospective study. Saudi Med J. 1995;16(5):402-409. Does not meet criteria for eligibility.
Arden NK, Major P, Poole JR, et al. Size at birth, adult intestinal calcium absorption and 1,25(OH)2 vitamin D. Qjm: Monthly Journal of the Association of Physicians. 2002;95(1):15-21. Does not meet criteria for eligibility. [pmid: 11834768].
Arneil G C. The return of infantile rickets to Britain. World Review of Nutrition & Dietetics 1969;10239–261. Does not meet criteria for eligibility.
Arnold CM, Busch AJ, Schachter CL, et al. The relationship of intrinsic fall risk factors to a recent history of falling in older women with osteoporosis. J Orthop Sports Phys Ther. 2005;35(7):452-460. Does not meet criteria for eligibility. [pmid: 16108586].
Ashby JP, Newman DJ, Rinsler MG. Is intact PTH a sensitive biochemical indicator of deranged calcium homeostasis in vitamin D deficiency?. Ann Clin Biochem. 1989;26(Pt 4):324-327. Does not meet criteria for eligibility. [pmid: 2788385].
Atiq Mehnaz, Fadoo Zehra, Naz Fouzia, et al. Myelofibrosis in severe vitamin D deficiency rickets. JPMA - Journal of the Pakistan Medical Association. 1999;49(7):174-177. Does not meet criteria for eligibility.
Avenell A, Handoll H H. Nutritional supplementation for hip fracture aftercare in the elderly.[update of Cochrane Database Syst Rev. 2000;(4):CD001880; PMID: 11034731]. [Review][77 refs]. Cochrane Database Syst Rev 2004;(1):CD001880. Does not meet criteria for eligibility.
Backstrom MC, Maki R, Kuusela AL, et al. Randomised controlled trial of vitamin D supplementation on bone density and biochemical indices in preterm infants. Archives of Disease in Childhood Fetal & Neonatal Edition. 1999;80(3):F161-F166. Does not meet criteria for eligibility. [pmid: 10212074].
Baker MR, Peacock M, Nordin BE. The decline in vitamin D status with age. Age & Ageing. 1980;9(4):249-252. Does not meet criteria for eligibility. [pmid: 6971044].
Balasubramanian S, Shivbalan So, Saravana Kumar P. Hypocalcemia due to vitamin D deficiency in exclusively breastfed infants. Indian Pediatr. 2006;43(3):247-251. Does not meet criteria for eligibility. [pmid: 16585820].
Balsan S. 25-hydroxycholecalciferol: effects in idiopathic vitamin D-resistant rickets. Calcif Tissue Res 1970;Suppl-6. Does not meet criteria for eligibility.
Balsan S, Garabedian M. 25- Hydroxycholecalciferol. A comparative study in deficiency rickets and different types of resistant rickets. Eur J Clin Invest. 1972;51(4):749-759. Does not meet criteria for eligibility.
Balsan S, Tieder M. Linear growth in patients with hypophosphatemic vitamin D-resistant rickets: influence of treatment regimen and parental height.[see comment]. Eur J Pediatr. 1990;116(3):365-371. Does not meet criteria for eligibility.
Balsan S, Garabedian M, Sorgniard R, et al. 1,25-dihydroxyvitamin D3 and 1, alpha-hydroxyvitamin D3 in children: biologic and therapeutic effects in nutritional rickets and different types of vitamin D resistance. Pediatr Res. 1975;9(7):586-593. Does not meet criteria for eligibility. [pmid: 169507].
Barger-Lux MJ, Heaney RP, Lanspa SJ, et al. An investigation of sources of variation in calcium absorption efficiency.[erratum appears in J Clin Endocrinol Metab 1995 Jul;80(7):2068]. Journal of Clinical Endocrinology & Metabolism. 1995;80(2):406-411. Does not meet criteria for eligibility. [pmid: 7852497].
Baroncelli GI, Federico G, Bertelloni S, et al. Vitamin-D receptor genotype. Does not predict bone mineral density, bone turnover, and growth in prepubertal children. Horm Res. 1999;51(3):150-156. Does not meet criteria for eligibility. [pmid: 10461021].
Barrueto F, Wang-Flores HH, Howland MA, et al. Acute vitamin D intoxication in a child. Pediatrics. 2005;116(3):e453-e456. Does not meet criteria for eligibility. [pmid: 16140692].
Bartl R. RECORD study: Secondary prevention of low-trauma fractures in elderly patients. Internist Prax. 2006;47(5):541-544. Does not meet criteria for eligibility.
Barzel US. Recommended testing in patients with low bone density.[comment]. Journal of Clinical Endocrinology & Metabolism. 2003;88(3):1404-1405. Does not meet criteria for eligibility. [pmid: 12629143].
Basha Bassem, Rao Sudhaker, Han Zei, et al. Osteomalacia due to vitamin D depletion: A neglected consequence of intestinal malabsorption. Am J Med. 2000;108(4):296-300. Does not meet criteria for eligibility. [pmid: 11014722].
Bashir T, Macdonald HN, Peacock M. Biochemical evidence of vitamin D deficiency in pregnant Asian women. J Hum Nutr. 1981;35(1):49-52. Does not meet criteria for eligibility. [pmid: 7204962].
Batch JA, Couper JJ, Rodda C, et al. Use of bisphosphonate therapy for osteoporosis in childhood and adolescence. Journal of Paediatrics & Child Health. 2003;39(2):88-92. Does not meet criteria for eligibility. [pmid: 12603794].
Bauman WA, Morrison NG, Spungen AM. Vitamin D replacement therapy in persons with spinal cord injury. J Spinal Cord Med. 2005;28(3):203-207. Does not meet criteria for eligibility. [pmid: 16048137].
Baumgartl HJ, Standl E, Schmidt-Gayk H, et al. Changes of vitamin D3 serum concentrations at the onset of immune-mediated type 1 (insulin-dependent) diabetes mellitus. Diabetes Res. 1991;16(3):145-148. [pmid: 1666347].
Beck B R, Shoemaker M R. Osteoporosis: understanding key risk factors and therapeutic options. Phys Sportsmed 2000;28(2):69–4, 76. Does not meet criteria for eligibility.
Bell NH. Hypercalcemic and hypocalcemic disorders: diagnosis and treatment. Nephron. 1979;23(23):147-151. Does not meet criteria for eligibility. [pmid: 440508].
Bell NH, Godsen RN, Henry DP, et al. The effects of muscle-building exercise on vitamin D and mineral metabolism. Journal of Bone & Mineral Research. 1988;3(4):369-373. Does not meet criteria for eligibility. [pmid: 3265576].
Bell NH, Williamson BT, Hollis BW, et al. Effects of race on diurnal patterns of renal conservation of calcium and bone resorption in premenopausal women. Osteoporos Int. 2001;12(1):43-48. Does not meet criteria for eligibility. [pmid: 11305082].
Belobradkova J, Hodan J. Primary vitamin D refractory rickets. Sb Ved Pr Lek Fak Karlovy Univerzity Hradci Kralove Suppl. 1969;12(3):325-329. Does not meet criteria for eligibility.
Benhamou CL, Tourliere D, Gauvain JB, et al. Calciotropic hormones in elderly people with and without hip fracture. Osteoporos Int. 1995;5(2):103-107. Does not meet criteria for eligibility. [pmid: 7599446].
Berg JP. Stronger bonds between 25-hydroxyvitamin D 1alpha-hydroxylase and pseudovitamin D-deficiency rickets. Eur J Endocrinol. 1998;138(3):264-265. Does not meet criteria for eligibility. [pmid: 9539299].
Bergenfelz A, Ahren B. Serum osteocalcin levels do not change during rapidly induced hypercalcemia in healthy subjects. Horm Res. 1992;37(12):29-32. Does not meet criteria for eligibility. [pmid: 1398473].
Berger Christian E, Marteau Robert, Pabinger Christoph, et al. Decreased cutaneous vitamin D-synthesis in heavily melanized individuals: A rare cause for pathologic fractures of the hip. Wien Klin Wochenschr. 2003;115(56):186-190. Does not meet criteria for eligibility. [pmid: 12741080].
Beringer TR, Ardill J, Taggart HM. Absence of evidence for a role of calcitonin in the etiology of femoral neck fracture. Calcif Tissue Int. 1986;39(5):300-303. Does not meet criteria for eligibility. [pmid: 3102019].
Beringer T, Heyburn G, Finch M, et al. Prevalence of vitamin D inadequacy in Belfast following fragility fracture. Current Medical Research & Opinion. 2006;22(1):101-105. Does not meet criteria for eligibility. [pmid: 16393436].
Berlyne GM. Parathyroid hormone and 25-hydroxyvitamin D concentrations in the elderly. British Medical Journal Clinical Research Ed. 1983;287(6402):1379. Does not meet criteria for eligibility. [pmid: 6416425].
Bhattoa HP, Kiss E, Bettembuk P, et al. Bone mineral density, biochemical markers of bone turnover, and hormonal status in men with systemic lupus erythematosus. Rheumatol Int. 2001;21(3):97-102. Does not meet criteria for eligibility. [pmid: 11765229].
Biale Y, Shany S, Levi M, et al. 25 Hydroxycholecalciferol levels in Beduin women in labor and in cord blood of their infants. Am J Clin Nutr. 1979;32(12):2380-2382. Does not meet criteria for eligibility. [pmid: 506960].
Bischoff-Ferrari HA, Conzelmann M, Stahelin HB, et al. Is fall prevention by vitamin D mediated by a change in postural or dynamic balance?. Osteoporos Int. 2006;17(5):656-663. Does not meet criteria for eligibility. [pmid: 16508700].
Bischoff-Ferrari HA, Dawson-Hughes B, Willett WC, et al. Effect of Vitamin D on falls: a meta-analysis. JAMA. 2004;291(16):1999-2006. Does not meet criteria for eligibility. [pmid: 15113819].
Biser-Rohrbaugh A, Hadley-Miller N. Vitamin d deficiency in breast-fed toddlers. J Pediatr Orthop. 2001;21(4):508-511. Does not meet criteria for eligibility. [pmid: 11433165].
Black DM. Screening and treatment in the elderly to reduce osteoporotic fracture risk. British Journal of Obstetrics & Gynaecology. 1996;103(SUPPL. 13):2-8. Does not meet criteria for eligibility. [pmid: 8624337].
Blumsohn Aubrey, Naylor Kim E, Timm Wolfram, et al. Seasonal variation present and biologically significant?. Journal of Bone & Mineral Research. 2004;19(1):170-171. Does not meet criteria for eligibility.
Bogaisky M, Leipzig R M. Vitamin D3, calcium, or both did not prevent secondary fractures in older persons. ACP J Club 2005;143(3):74, 72–74, 73. Does not meet criteria for eligibility.
Bogaisky M, Leipzig R M. Calcium and vitamin D supplementation did not reduce fractures in women greater than or equal to 70 years of age. ACP J Club 2005;143(3):73, 72, 74. Does not meet criteria for eligibility.
Bonofiglio D, Maggiolini M, Catalano S, et al. Parathyroid hormone is elevated but bone markers and density are normal in young female subjects who consume inadequate dietary calcium. Br J Nutr. 2000;84(1):111-116. Does not meet criteria for eligibility. [pmid: 10961167].
Bonofiglio D, Maggiolini M, Marsico S, et al. Critical years and stages of puberty for radial bone mass apposition during adolescence. Hormone & Metabolic Research. 1999;31(8):478-482. Does not meet criteria for eligibility. [pmid: 10494875].
Boonen S, Rizzoli R, Meunier PJ, et al. The need for clinical guidance in the use of calcium and vitamin D in the management of osteoporosis: A consensus report. Osteoporos Int. 2004;15(7):511-519. Does not meet criteria for eligibility. [pmid: 15069595].
Boonen Steven, Vanderschueren Dirk, Cheng Xiao, et al. Age-related (Type II) femoral neck osteoporosis in men: Biochemical evidence for both hypovitaminosis D- and androgen deficiency-induced bone resorption. Journal of Bone & Mineral Research. 1997;12(12):2119-2126. Does not meet criteria for eligibility. [pmid: 9421246].
Boothby LA. Bisphosphonates for the prevention and treatment of osteoporosis. P & T. 2002;27(10):506-513. Does not meet criteria for eligibility.
Bordier P, Hioco D, Rouquier M, et al. Effects of intravenous vitamin D on bone and phosphate metabolism in osteomalacia. Calcif Tissue Res. 1969;4(1):78-83. Does not meet criteria for eligibility. [pmid: 5344411].
Bordier P, Rasmussen H, Marie P, et al. Vitamin D metabolites and bone mineralization in man. Journal of Clinical Endocrinology & Metabolism. 1978;46(2):284-294. Does not meet criteria for eligibility. [pmid: 750606].
Boucher BJ. Serum retinol levels and fracture risk.[comment]. N Engl J Med. 2003;348(19):1927-1928. Does not meet criteria for eligibility. [pmid: 12736290].
Briefel R, Hanson C, Fox M K et al. Feeding Infants and Toddlers Study: do vitamin and mineral supplements contribute to nutrient adequacy or excess among US infants and toddlers?. J Am Diet Assoc 2006;106(1):Supplement-65. Does not meet criteria for eligibility.
Brot C, Jorgensen NR, Sorensen OH. The influence of smoking on vitamin D status and calcium metabolism. Eur J Clin Nutr. 1999;53(12):920-926. Does not meet criteria for eligibility. [pmid: 10602348].
Brunvand L, Haug E. Vitamin D deficiency amongst Pakistani women in Oslo. Acta Obstet Gynecol Scand. 1993;72(4):264-268. Does not meet criteria for eligibility. [pmid: 8389512].
Brunvand L, Quigstad E, Urdal P, et al. Vitamin D deficiency and fetal growth. Early Hum Dev. 1996;45(12):27-33. Does not meet criteria for eligibility. [pmid: 8842637].
Brunvand L, Shah SS, Bergstrom S, et al. Vitamin D deficiency in pregnancy is not associated with obstructed labor. A study among Pakistani women in Karachi. Acta Obstet Gynecol Scand. 1998;77(3):303-306. Does not meet criteria for eligibility. [pmid: 9539276].
Bruyere O, Edwards J, Reginster J. Clinical Evidence Concise. Fracture prevention in postmenopausal women. Am Fam Physician. 2005;71(11):2151-2152. Does not meet criteria for eligibility.
Brzozowska A, Enzi G, Amorin Cruz J. Medicine use and supplementation practice among participants of SENECA Study. J Nutr Health Aging. 2002;6(1):34-38. Does not meet criteria for eligibility. [pmid: 11813079].
Buchanan JR, Santen RJ, Cavaliere A, et al. Interaction between parathyroid hormone and endogenous estrogen in normal women. Metabolism: Clinical & Experimental. 1986;35(6):489-494. Does not meet criteria for eligibility. [pmid: 3754923].
Buckle RM, Gamlen TR, Pullen IM. Vitamin D intoxication treated with porcine calcitonin. Br Med J. 1972;3(820):205-207. Does not meet criteria for eligibility. [pmid: 4261142]. [pmcid: 1785685].
Buntain HM, Greer RM, Schluter PJ, et al. Bone mineral density in Australian children, adolescents and adults with cystic fibrosis: a controlled cross sectional study. Thorax. 2004;59(2):149-155. Does not meet criteria for eligibility. [pmid: 14760157]. [pmcid: 1746947].
Burns J, Paterson CR. Single dose vitamin D treatment for osteomalacia in the elderly. British Medical Journal Clinical Research Ed. 1985;290(6464):281-282. Does not meet criteria for eligibility. [pmid: 3917785].
Burns J, Davidson AV, MacLennan WJ, et al. The value of serum 25-hydroxyvitamin D assays in screening elderly patients for vitamin D deficiency. Journal of Clinical & Experimental Gerontology. 1985;7(3):213-222. Does not meet criteria for eligibility.
Butler Meg, Norton Robyn, Lee-Joe Trevor et al. Preventing falls and fall-related injuries among older people living in institutions: Current practice and future opportunities. N Z Med J 1998;111(1074):25, 1998-361. Does not meet criteria for eligibility.
Buysschaert M, Lejeune D, Esselinckx W, et al. Treatment of postmenopausal osteoporosis with vitamin D and severe hypercalcemia. Acta Clin Belg. 1984;39(3):171-173. Does not meet criteria for eligibility. [pmid: 6091383].
Calvo MS, Whiting SJ. Prevalence of vitamin D insufficiency in Canada and the United States: Importance to health status and efficacy of current food fortification and dietary supplement use. Nutr Rev. 2003;61(3):107-113. Does not meet criteria for eligibility. [pmid: 12723644].
Calvo MS, Whiting SJ, Barton CN. Vitamin D fortification in the United States and Canada: current status and data needs. Am J Clin Nutr. 2004;80(6 Suppl):1710S-1716S. Does not meet criteria for eligibility. [pmid: 15585792].
Campbell AJ, Robertson MC, La Grow SJ, et al. Randomised controlled trial of prevention of falls in people aged > or =75 with severe visual impairment: the VIP trial. BMJ. 2005;331(7520):817. Does not meet criteria for eligibility. [pmid: 16183652]. [pmcid: 1246082].
Campbell BG, Ketchell D, Gunning K. Clinical inquiries. Do calcium supplements prevent postmenopausal osteoporotic fractures?. [Review] [13 refs]. J Fam Pract. 2003;52(3):234-237. Does not meet criteria for eligibility. [pmid: 12620181].
Caniggia A, Nuti R, Lore F, et al. Long-term treatment with calcitriol in postmenopausal osteoporosis. Metabolism: Clinical & Experimental. 1990;39(4 Suppl 1):43-49. Does not meet criteria for eligibility. [pmid: 2325571].
Cardinal H, Brossard JH, Roy L, et al. The set point of parathyroid hormone stimulation by calcium is normal in progressive renal failure. Journal of Clinical Endocrinology & Metabolism. 1998;83(11):3839-3844. Does not meet criteria for eligibility. [pmid: 9814455].
Carmeliet G, Van Cromphaut S, Daci E, et al. Disorders of calcium homeostasis. [Review] [70 refs]. Best Practice & Research Clinical Endocrinology & Metabolism. 2003;17(4):529-546. Does not meet criteria for eligibility. [pmid: 14687587].
Carter GD, Carter R, Jones J, et al. How accurate are assays for 25-hydroxyvitamin D? Data from the international vitamin D external quality assessment scheme. Clin Chem. 2004;50(11):2195-2197. Does not meet criteria for eligibility. [pmid: 15375018].
Casella SJ, Reiner BJ, Chen TC, et al. A possible genetic defect in 25-hydroxylation as a cause of rickets.[see comment]. Eur J Pediatr. 1994;124(6):929-932. Does not meet criteria for eligibility.
Chailurkit LO, Pongchaiyakul C, Charoenkiatkul S, et al. Different mechanism of bone loss in ageing women and men in Khon Kaen Province. J Med Assoc Thai. 2001;84(8):1175-1182. Does not meet criteria for eligibility. [pmid: 11758855].
Chailurkit LO, Rajatanavin R, Teerarungsikul K, et al. Serum vitamin D, parathyroid hormone and biochemical markers of bone turnover in normal Thai subjects. J Med Assoc Thai. 1996;79(8):499-504. Does not meet criteria for eligibility. [pmid: 8855632].
Challa A, Apazidou H, Tzoufi M, et al. Nutritional rickets revisited in children of Albanian origin (two cases). Adv Food Nutr Res. 2003;23(11):1495-1502. Does not meet criteria for eligibility.
Challem J. Medical journal watch: Context and applications. Alternative & Complementary Therapies. 2006;12(2):102-106. Does not meet criteria for eligibility.
Chan GM. Dietary calcium and bone mineral status of children and adolescents.[see comment]. Am J Dis Child. 1991;145(6):631-634. Does not meet criteria for eligibility. [pmid: 2035492].
Chan GM, Mileur LJ. Posthospitalization growth and bone mineral status of normal preterm infants. Feeding with mother's milk or standard formula. Am J Dis Child. 1985;139(9):896-898. Does not meet criteria for eligibility. [pmid: 3839970].
Chan GM, Hess M, Hollis J, et al. Bone mineral status in childhood accidental fractures.[see comment]. Am J Dis Child. 1984;138(6):569-570. Does not meet criteria for eligibility. [pmid: 6720643].
Chapuy MC, Arlot M. Prevention of non vertebral fractures and cortical bone loss in elderly women: a prospective controlled trial using calcium and vitamin D3 supplements [abstract]. Osteoporos-Int. 1993;3(Suppl. 1):258. Does not meet criteria for eligibility.
Chapuy MC, Arlot ME, Delmas PD, et al. Effect of calcium and cholecalciferol treatment for three years on hip fractures in elderly women. Br Med J. 1994;308(6936):1081-1082. Does not meet criteria for eligibility. [pmid: 8173430]. [pmcid: 2539939].
Chary-Valckenaere I, Blum A, Pere P, et al. Insufficiency fractures of the ilium.[see comment]. Revue du Rhumatisme (English Edition). 1997;64(10):542-548. Does not meet criteria for eligibility.
Chaussain-Miller C, Sinding C, Wolikow M, et al. Dental abnormalities in patients with familial hypophosphatemic vitamin D-resistant rickets: prevention by early treatment with 1-hydroxyvitamin D. Eur J Pediatr. 2003;142(3):324-331. Does not meet criteria for eligibility.
Chen JS, Cameron ID, Cumming RG, et al. Effect of age-related chronic immobility on markers of bone turnover. Journal of Bone & Mineral Research. 2006;21(2):324-331. Does not meet criteria for eligibility. [pmid: 16418789].
Chen JY, Ling UP, Chiang WL, et al. Total body bone mineral content in small-for-gestational -age, appropriate-for-gestational -age, large-for-gestational -age term infants and appropriate-for-gestational -age preterm infants. Chung Hua i Hsueh Tsa Chih - Chinese Medical Journal. 1995;56(2):109-114. Does not meet criteria for eligibility.
Chertow Glenn M. (Untitled). Nephrology Dialysis Transplantation. 2001;16(2):429-430. Does not meet criteria for eligibility.
Chesney RW, Mazess RB, Rose P, et al. Long-term influence of calcitriol (1,25-dihydroxyvitamin D) and supplemental phosphate in X-linked hypophosphatemic rickets. Pediatrics. 1983;71(4):559-567. Does not meet criteria for eligibility. [pmid: 6300745].
Chesney Russell W. Rickets: An old form for a new century. Pediatr Int. 2003;45(5):509-511. Does not meet criteria for eligibility. [pmid: 14521522].
Christiansen C, Rodbro P. Serum vitamin D metabolites in younger and elderly postmenopausal women. Calcif Tissue Int. 1984;36(1):19-24. Does not meet criteria for eligibility. [pmid: 6423232].
Christiansen C, Christensen MS, McNair P, et al. Vitamin D metabolites in diabetic patients: decreased serum concentration of 24,25-dihydroxyvitamin D. Scandinavian Journal of Clinical & Laboratory Investigation. 1982;42(6):487-491. Does not meet criteria for eligibility. [pmid: 6760373].
Cifuentes RF, Kooh SW, Radde IC. Vitamin D deficiency in a calcium-supplemented very low-birth-weight infant. Eur J Pediatr. 1980;96(2):252-255. Does not meet criteria for eligibility.
Cigolini M, Miconi V, Soffiati G, et al. Hypovitaminosis D among unselected medical inpatients and outpatients in Northern Italy [2]. Clin Endocrinol (Oxf). 2006;64(4):475. Does not meet criteria for eligibility. [pmid: 16584525].
Cohanim M, DeLuca HF, Yendt ER. Effects of prolonged treatment with 25-hydroxycholecalciferol in hypophosphatemic (vitamin D refractory) rickets and osteomalacia. Johns Hopkins Med J Suppl. 1972;131(2):118-132. Does not meet criteria for eligibility.
Cohen HN, Fogelman I, Boyle IT, et al. Deafness due to hypervitaminosis D. Lancet. 1979;1(8123):985. Does not meet criteria for eligibility. [pmid: 87663].
Cole PA, Bhandari M. What's new in orthopaedic trauma. Journal of Bone & Joint Surgery - American Volume. 2005;87(12 I):2823-2838. Does not meet criteria for eligibility.
Colic-Baric I, Kajfez R, Satalic Z, et al. Comparison of dietary habits in the urban and rural Croatian schoolchildren. Eur J Nutr. 2004;43(3):169-174. Does not meet criteria for eligibility. [pmid: 15168039].
Coll PP. Vitamin D deficiency in long-term care residents. Annals of Long Term Care. 2006;14(3):36-37. Does not meet criteria for eligibility.
Compston JE, Silver AC, Croucher PI, et al. Elevated serum intact parathyroid hormone levels in elderly patients with hip fracture. Clin Endocrinol (Oxf). 1989;31(6):667-672. Does not meet criteria for eligibility. [pmid: 2627757].
Compston Juliet E. The role of vitamin D and calcium supplementation in the prevention of osteoporotic fractures in the elderly. Clin Endocrinol (Oxf). 1995;43(4):393-405. Does not meet criteria for eligibility. [pmid: 7586612].
Connors MH, Sheikholislam BM, Irias JJ. Vitamin D toxicity after dieting in hypoparathyroidism. Pediatrics. 1976;57(5):794-796. Does not meet criteria for eligibility. [pmid: 1084987].
Cooke R, Hollis B, Conner C, et al. Vitamin D and mineral metabolism in the very low birth weight infant receiving 400 IU of vitamin D. Eur J Pediatr. 1990;116(3):423-428. Does not meet criteria for eligibility.
Corless D, Dawson E. Failure of calciferol to improve physical capabilities in elderly hospital patients with low or normal plasma 25 hydroxyvitamin D [abstract]. Clin-Sci. 1984;67(Supl. 9):16P. Does not meet criteria for eligibility.
Cortet B, Bera-Louville A, Gauthier P, et al. Comparative efficacy and safety study of etidronate and alendronate in postmenopausal osteoporosis. effect of adding hormone replacement therapy. Joint, Bone, Spine: Revue du Rhumatisme. 2001;68(5):410-415. Does not meet criteria for eligibility.
Cosman F, Morgan DC, Nieves JW, et al. Resistance to bone resorbing effects of PTH in black women. Journal of Bone & Mineral Research. 1997;12(6):958-966. Does not meet criteria for eligibility. [pmid: 9169356].
Cosman F, Shen V, Morgan D, et al. Biochemical responses of bone metabolism to 1,25-dihydroxyvitamin D administration in black and white women. Osteoporos Int. 2000;11(3):271-277. Does not meet criteria for eligibility. [pmid: 10824245].
Crofton PM. What is the cause of benign transient hyperphosphatasemia? A study of 35 cases. Clin Chem. 1988;34(2):335-340. Does not meet criteria for eligibility. [pmid: 3342506].
Cross NA, Hillman LS, Allen SH, et al. Changes in bone mineral density and markers of bone remodeling during lactation and postweaning in women consuming high amounts of calcium. Journal of Bone & Mineral Research. 1995;10(9):1312-1320. Does not meet criteria for eligibility. [pmid: 7502702].
Curino A, Skliar M, Boland R. Identification of 7-dehydrocholesterol, vitamin D3, 25(OH)-vitamin D3 and 1,25(OH)2-vitamin D3 in Solanum glaucophyllum cultures grown in absence of light. Biochim Biophys Acta. 1998;1425(3):485-492. Does not meet criteria for eligibility. [pmid: 9838212].
Dahl MV, Holick MF. Sun Exposure, Vitamin D Metabolism, and Skin Cancer [4] (multiple letters). Mayo Clin Proc. 2004;79(5):699-701. Does not meet criteria for eligibility. [pmid: 15132420].
Dandona P, Mohiuddin J, Weerakoon JW, et al. Persistence of parathyroid hypersecretion after vitamin D treatment in Asian vegetarians. Journal of Clinical Endocrinology & Metabolism. 1984;59(3):535-537. Does not meet criteria for eligibility. [pmid: 6611345].
Daniels ED, Pettifor JM, Schnitzler CM, et al. Differences in mineral homeostasis, volumetric bone mass and femoral neck axis length in black and white South African women. Osteoporos Int. 1997;7(2):105-112. Does not meet criteria for eligibility. [pmid: 9166389].
Dastur DK, Gagrat BM, Wadia NH, et al. Nature of muscular change in osteomalacia: light- and electron-microscope observations. Am J Pathol. 1975;117(4):211-228. Does not meet criteria for eligibility.
Davey D A. Vitamin D and its analogues and the prevention and treatment of osteoporosis. S Afr Med J 1997;Suid-Afrikaanse Tydskrif Vir Geneeskunde. 87(4):423–425. Does not meet criteria for eligibility.
Davidson CW, Merrilees Megan J, Wilkinson Tim J, et al. Hip fracture mortality and morbidity: Can we do better?. N Z Med J. 2001;114(1136):329-331. Does not meet criteria for eligibility. [pmid: 11548098].
Davidson WM. Comparative effects of vitamin D and 25-hydroxycholecalciferol on the calcium content of cultured bone rudiments. Pharmacology & Therapeutics in Dentistry. 1975;2(34):223-228. Does not meet criteria for eligibility.
Davie M, Lawson DE, Jung RT. Low plasma-25-hydroxyvitamin D without osteomalacia. Lancet. 1978;1(8068):820. Does not meet criteria for eligibility. [pmid: 85831].
Davies M, Adams PH. The continuing risk of vitamin-D intoxication. Lancet. 1978;2(8090):621-623. Does not meet criteria for eligibility. [pmid: 80540].
Davies M, Adams PH, Berry JL, et al. Familial hypocalciuric hypercalcaemia: observations on vitamin D metabolism and parathyroid function. Acta Endocrinol (Copenh). 1983;104(2):210-215. Does not meet criteria for eligibility. [pmid: 6314724].
Davies M, Hayes ME, Yin JA, et al. Abnormal synthesis of 1,25-dihydroxyvitamin D in patients with malignant lymphoma. Journal of Clinical Endocrinology & Metabolism. 1994;78(5):1202-1207. Does not meet criteria for eligibility. [pmid: 8175979].
Dawson-Hughes B. Racial/ethnic considerations in making recommendations for vitamin D for adult and elderly men and women. Am J Clin Nutr. 2004;80(6 Suppl):1763S-1766S. Does not meet criteria for eligibility. [pmid: 15585802].
Dawson-Hughes B. Calcium plus vitamin D and the risk of fractures.[comment]. N Engl J Med. 2006;354(21):2285-2287. Does not meet criteria for eligibility. [pmid: 16729367].
Dawson-Hughes B, Harris SS. Calcium intake influences the association of protein intake with rates of bone loss in elderly men and women.[see comment]. Am J Clin Nutr. 2002;75(4):773-779. Does not meet criteria for eligibility. [pmid: 11916767].
De Torrente, De La, Jara Pecoud A, et al. Lesson of the week: Musculoskeletal pain in female asylum seekers and hypovitaminosis D3. Br Med J. 2004;329(7458):156-157. Does not meet criteria for eligibility. [pmid: 15258072]. [pmcid: 478229].
Delmez JA, Tindira C, Grooms P, et al. Parathyroid hormone suppression by intravenous 1,25-dihydroxyvitamin D. A role for increased sensitivity to calcium. Eur J Clin Invest. 1989;83(4):1349-1355. Does not meet criteria for eligibility.
Delmi M, Rapin CH, Bengoa JM, et al. Dietary supplementation in elderly patients with fractured neck of the femur.[see comment]. Lancet. 1990;335(8696):1013-1016. Does not meet criteria for eligibility. [pmid: 1970070].
DeLucia MC, Carpenter TO. Rickets in the sunshine?. Adv Nutr Res. 2002;18(1):97-99. Does not meet criteria for eligibility.
Delvin EE, Glorieux FH, Salle BL, et al. Control of vitamin D metabolism in preterm infants: feto-maternal relationships. Arch Dis Child. 1982;57(10):754-757. Does not meet criteria for eligibility. [pmid: 7138064]. [pmcid: 1627903].
Demiaux B, Arlot ME, Chapuy MC, et al. Serum osteocalcin is increased in patients with osteomalacia: correlations with biochemical and histomorphometric findings. Journal of Clinical Endocrinology & Metabolism. 1992;74(5):1146-1151. Does not meet criteria for eligibility. [pmid: 1569162].
Demiaux-Domenech B, Bonjour JP, Rizzoli R. Axial osteomalacia: report of a new case with selective increase in axial bone mineral density. Bone. 1996;18(6):633-637. Does not meet criteria for eligibility. [pmid: 8806007].
Dequeker J, Bouillon R. Parathyroid hormone secretion and 25-hydroxyvitamin D levels in primary osteoporosis. Calcif Tissue Res. 1977;22(Suppl):495-496. Does not meet criteria for eligibility. [pmid: 912573].
Dhonukshe-Rutten RA, Lips M, de Jong N, et al. Vitamin B-12 status is associated with bone mineral content and bone mineral density in frail elderly women but not in men. Br J Nutr. 2003;133(3):801-807. Does not meet criteria for eligibility.
Di Monaco M, Vallero F, Di Monaco R, et al. Serum levels of 25-hydroxyvitamin D and functional recovery after hip fracture. Archives of Physical Medicine & Rehabilitation. 2005;86(1):64-68. Does not meet criteria for eligibility. [pmid: 15640991].
Di Munno O, Beghe F, Favini P, et al. Prevention of glucocorticoid-induced osteopenia: effect of oral 25-hydroxyvitamin D and calcium. Clin Rheumatol. 1989;8(2):202-207. Does not meet criteria for eligibility. [pmid: 2758767].
Dietrich T, Joshipura KJ, Dawson-Hughes B, et al. Association between serum concentrations of 25-hydroxyvitamin D3 and periodontal disease in the US population. Am J Clin Nutr. 2004;80(1):108-113. Does not meet criteria for eligibility. [pmid: 15213036].
Doetsch AM, Faber J, Lynnerup N, et al. The effect of calcium and vitamin D3 supplementation on the healing of the proximal humerus fracture: a randomized placebo-controlled study. Calcif Tissue Int. 2004;75(3):183-188. Does not meet criteria for eligibility. [pmid: 15386160].
Dominguez JH, Gray RW, Lemann J. Dietary phosphate deprivation in women and men: effects on mineral and acid balances, parathyroid hormone and the metabolism of 25-OH-vitamin D. Journal of Clinical Endocrinology & Metabolism. 1976;43(5):1056-1068. Does not meet criteria for eligibility. [pmid: 11224].
Douglas AS, Robins SP, Hutchison JD, et al. Carboxylation of osteocalcin in post-menopausal osteoporotic women following vitamin K and D supplementation. Bone. 1995;17(1):15-20. Does not meet criteria for eligibility. [pmid: 7577153].
Down PF, Polak A, Regan RJ. A family with massive acute vitamin D intoxication. Postgrad Med J. 1979;55(654):897-902. Does not meet criteria for eligibility. [pmid: 232912]. [pmcid: 2425685].
Drinka PJ. The importance of parathyroid hormone and vitamin D status in the treatment of osteoporosis and renal insufficiency.[see comment]. [Review] [47 refs]. J Am Med Dir Assoc. 2004;5(6):382-386. Does not meet criteria for eligibility. [pmid: 15530176].
Duda Grazyna, Przyslawski Juliusz. Dietary risk factors for osteoporosis in the elderly. Polish Journal of Food & Nutrition Sciences. 2002;11(3):87-91. Does not meet criteria for eligibility.
Dukas LC, Schacht E, Mazor Z, et al. A new significant and independent risk factor for falls in elderly men and women: a low creatinine clearance of less than 65 ml/min. Osteoporos Int. 2005;16(3):332-338. Does not meet criteria for eligibility. [pmid: 15241585].
Dunnigan MG, Henderson JB, Hole DJ, et al. Meat consumption reduces the risk of nutritional rickets and osteomalacia. Br J Nutr. 2005;94(6):983-991. Does not meet criteria for eligibility. [pmid: 16351777].
Dunnigan Matthew G, Henderson Janet B. An epidemiological model of privational rickets and osteomalacia. Proc Nutr Soc. 1997;56(3):939-956. Does not meet criteria for eligibility. [pmid: 9483661].
Duplechin RY, Nadkarni M, Schwartz RP. Hypocalcemic tetany in a toddler with undiagnosed rickets. Ann Emerg Med. 1999;34(3):399-402. Does not meet criteria for eligibility. [pmid: 10459099].
Earp HS, Ney RL, Gitelman HJ, et al. Effects of 25-hydroxycholecalciferol in patients with familial hypophosphatemia and vitamin-D-resistant rickets. N Engl J Med. 1970;283(12):627-630. Does not meet criteria for eligibility. [pmid: 4317911].
Eastell Richard, Lambert Helen. Diet and healthy bones. Calcif Tissue Int. 2002;70(5):400-404. Does not meet criteria for eligibility. [pmid: 11960202].
Eastwood JB, De Wardener HE, Gray RW, et al. Normal plasma-1,25-(OH)2-vitamin-D concentrations in nutritional osteomalacia. Lancet. 1979;1(8131):1377-1378. Does not meet criteria for eligibility. [pmid: 87836].
Ebeling PR. Megadose therapy for vitamin D deficiency. Med J Aust. 2005;183(1):04. Does not meet criteria for eligibility.
Ebeling PR, Sandgren ME, DiMagno EP, et al. Evidence of an age-related decrease in intestinal responsiveness to vitamin D: relationship between serum 1,25-dihydroxyvitamin D3 and intestinal vitamin D receptor concentrations in normal women. Journal of Clinical Endocrinology & Metabolism. 1992;75(1):176-182. Does not meet criteria for eligibility. [pmid: 1320048].
El Desouki MI, Othman SM, Fouda MA. Bone mineral density and bone scintigraphy in adult Saudi female patients with osteomalacia. Saudi Med J. 2004;25(3):355-358. Does not meet criteria for eligibility. [pmid: 15048176].
Engels Y, van Assema P, Dorant E, et al. Factors associated with the intention to use vitamin D supplements: quantitative study among a sample of elderly people in a medium-sized town in the Netherlands. J Nutr Educ. 2001;33(3):134-142. Does not meet criteria for eligibility. [pmid: 11953228].
Ensrud KE, Stone K, Cauley JA, et al. Vitamin D receptor gene polymorphisms and the risk of fractures in older women. For the Study of Osteoporotic Fractures Research Group. Journal of Bone & Mineral Research. 1999;14(10):1637-1645. Does not meet criteria for eligibility. [pmid: 10491209].
Eriksen EF, Glerup H. Vitamin D deficiency and aging: implications for general health and osteoporosis. Biogerontology. 2002;3(12):73-77. Does not meet criteria for eligibility. [pmid: 12014847].
Eriksen EF, Mosekilde L, Melsen F. Effect of sodium fluoride, calcium, phosphate, and vitamin D2 on trabecular bone balance and remodeling in osteoporotics. Bone. 1985;6(5):381-389. Does not meet criteria for eligibility. [pmid: 3879454].
Erkkola M, Karppinen M, Jarvinen A, et al. Folate, vitamin D, and iron intakes are low among pregnant Finnish women. Eur J Clin Nutr. 1998;52(10):742-748. Does not meet criteria for eligibility. [pmid: 9805222].
Ettinger MP, Felsenberg D, Harris ST, et al. Safety and tolerability of oral daily and intermittent ibandronate are not influenced by age. Br J Rheumatol. 2005;32(10):1968-1974. Does not meet criteria for eligibility.
Evans JR, Allen AC, Stinson DA, et al. Effect of high-dose vitamin D supplementation on radiographically detectable bone disease of very low birth weight infants. Eur J Pediatr. 1989;115(5 Pt 1):779-786. Does not meet criteria for eligibility.
Evans TR, Colston KW, Lofts FJ, et al. A phase II trial of the vitamin D analogue Seocalcitol (EB1089) in patients with inoperable pancreatic cancer. Br J Cancer. 2002;86(5):680-685. Does not meet criteria for eligibility. [pmid: 11875725].
Even Lea, Weisman Yosef, Goldray David, et al. Selective modulation by vitamin D of renal response to parathyroid hormone: A study in calcitriol-resistant rickets. Journal of Clinical Endocrinology & Metabolism. 1996;81(8):2836-2840. Does not meet criteria for eligibility. [pmid: 8768839].
Eventov I, Frisch B, Alk D, et al. Bone biopsies and serum vitamin-D levels in patients with hip fracture. Acta Orthop Scand. 1989;60(4):411-413. Does not meet criteria for eligibility. [pmid: 2816317].
Fahraeus B, Andersson L, Bergdahl L, et al. Postoperative hypoparathyroidism. Hazards from vitamin D therapy. Acta Chir Scand. 1973;139(5):437-441. Does not meet criteria for eligibility. [pmid: 4542958].
Fahrleitner A, Dobnig H, Obernosterer A, et al. Vitamin D deficiency and secondary hyperparathyroidism are common complications in patients with peripheral arterial disease.[see comment]. J Gen Intern Med. 2002;17(9):663-669. Does not meet criteria for eligibility. [pmid: 12220361]. [pmcid: 1495101].
Fairney A, Naughten E, Oppe TE. Vitamin D and human lactation. Lancet. 1977;2(8041):739-741. Does not meet criteria for eligibility. [pmid: 71543].
Falch JA, Mowe M, Bohmer T, et al. Serum levels of intact parathyroid hormone in elderly patients with hip fracture living at home. Acta Endocrinol (Copenh). 1992;126(1):10-12. Does not meet criteria for eligibility. [pmid: 1310560].
Falch JA, Odegaard OR, Finnanger AM, et al. Postmenopausal osteoporosis: no effect of three years treatment with 1,25-dihydroxycholecalciferol. Acta Med Scand. 1987;221(2):199-204. Does not meet criteria for eligibility. [pmid: 3035879].
Falch JA, Oftebro H, Haug E. Early postmenopausal bone loss is not associated with a decrease in circulating levels of 25-hydroxyvitamin D, 1,25-dihydroxyvitamin D, or vitamin D-binding protein. Journal of Clinical Endocrinology & Metabolism. 1987;64(4):836-841. Does not meet criteria for eligibility. [pmid: 3818905].
Fehily AM, Coles RJ, Evans WD, et al. Factors affecting bone density in young adults. Am J Clin Nutr. 1992;56(3):579-586. Does not meet criteria for eligibility. [pmid: 1503072].
Feit JM. Calcium and vitamin D supplements for elderly patients. J Fam Pract. 1997;45(6):471-472. Does not meet criteria for eligibility. [pmid: 9420580].
Feleke Y, Abdulkadir J, Mshana R, et al. Low levels of serum calcidiol in an African population compared to a North European population. Eur J Endocrinol. 1999;141(4):358-360. Does not meet criteria for eligibility. [pmid: 10526248].
Feliciano ES, Ho ML, Specker BL, et al. Seasonal and geographical variations in the growth rate of infants in China receiving increasing dosages of vitamin D supplements. J Trop Pediatr. 1994;40(3):162-165. Does not meet criteria for eligibility. [pmid: 8078115].
Fetter WP, Mettau JW, Degenhart HJ, et al. Plasma 1.25-dihydroxyvitamin D concentrations in preterm infants. Acta Paediatr Scand. 1985;74(4):549-554. Does not meet criteria for eligibility. [pmid: 3927655].
Finkelstein JS. Calcium plus vitamin D for postmenopausal women - Bone appetit?. N Engl J Med. 2006;354(7):750-752. Does not meet criteria for eligibility. [pmid: 16481643].
Fisher AA, Davis MW, Goh S, et al. The second hip fracture - An analysis of 84 elderly patients (multiple letters) [1]. J Orthop Trauma. 2004;18(4):256-257. Does not meet criteria for eligibility. [pmid: 15087975].
Fisher AA, Davis MW, Smith PN, et al. Undertreatment of osteoporosis following hip fracture [8] (multiple letters). Journal of Bone & Joint Surgery - American Volume. 2003;85(7):1394-1396. Does not meet criteria for eligibility.
Fleischman AR, Rosen JF, Nathenson G. 25-hydroxyvitamin D. Serum levels and oral administration of calcifediol in neonates. Arch Intern Med. 1978;138(Spec No):869-873. Does not meet criteria for eligibility. [pmid: 646577].
Fleurence RL. Cost-effectiveness of fracture prevention treatments in the elderly. Int J Technol Assess Health Care. 2004;20(2):184-191. Does not meet criteria for eligibility. [pmid: 15209178].
Flicker L, MacInnis R, Stein M et al. Should older people in residential care be supplemented with vitamin D to prevent falls? Results of a randomised trial [abstract]. 14th National Conference on Falls and Postural Instability, 2003, London. 2003. Excluded as an abstract.
Fogelman I. Where now for the management of osteoporosis?. Hospital Medicine (London). 2005;66(5):284-287. Does not meet criteria for eligibility.
Forli L, Halse J, Haug E, et al. Vitamin D deficiency, bone mineral density and weight in patients with advanced pulmonary disease. J Intern Med. 2004;256(1):56-62. Does not meet criteria for eligibility. [pmid: 15189366].
Fradinger EE. Letter re: 25-OH-vitamin D assays.[comment]. Journal of Clinical Endocrinology & Metabolism. 2005;90(11):6337-6338. Does not meet criteria for eligibility. [pmid: 16275982].
Frame B. Osteomalacia—current concepts. 1982. Ir J Med Sci. 1983;152(7 Suppl):3-11. Does not meet criteria for eligibility. [pmid: 6688612].
Francis RM, Peacock M. Local action of oral 1,25-dihydroxycholecalciferol on calcium absorption in osteoporosis. Am J Clin Nutr. 1987;46(2):315-318. Does not meet criteria for eligibility. [pmid: 3618534].
Francis RM, Baillie SP, Chuck AJ, et al. Management of osteoporosis in patients with hip fractures. QJM. 2000;93(8):501-506. Does not meet criteria for eligibility. [pmid: 10924531].
Francis RM, Peacock M, Storer JH, et al. Calcium malabsorption in the elderly: the effect of treatment with oral 25-hydroxyvitamin D3. Eur J Clin Invest. 1983;13(5):391-396. Does not meet criteria for eligibility. [pmid: 6416853].
Fraser DR. Vitamin D-deficiency in Asia. [Review] [12 refs]. Journal of Steroid Biochemistry & Molecular Biology. 2004;89–90(15):491-495. Does not meet criteria for eligibility.
Frederich A, Guibaud P, David M. [Comparative effects of 25-hydroxycholecalciferol and vitamin D in the treatment of hypocalcemia caused by D-avitaminosis in children]. [French]. Therapie. 1974;29(5):681-691. Non-english publication. [pmid: 4462222].
Freitag A, Barzel US. Differential diagnosis of osteoporosis. Gerontology. 2002;48(2):98-102. Does not meet criteria for eligibility. [pmid: 11867932].
Fujisawa Y, Kida K, Matsuda H. Role of change in vitamin D metabolism with age in calcium and phosphorus metabolism in normal human subjects. Journal of Clinical Endocrinology & Metabolism. 1984;59(4):719-726. Does not meet criteria for eligibility. [pmid: 6541227].
Fujisawa Y, Yamashita K, Hirai N, et al. Transient late neonatal hypocalcemia with high serum parathyroid hormone. J Pediatr Endocrinol. 1997;10(4):433-436. Does not meet criteria for eligibility.
Fuller Kathleen E, Casparian J, Michael. Vitamin D: Balancing cutaneous and systemic considerations. South Med J. 2001;94(1):58-64. Does not meet criteria for eligibility. [pmid: 11213944].
Gajewska J, Ambroszkiewicz J, Hozyasz KK. Markers of bone turnover in prepubertal children with celiac disease. Indian J Gastroenterol. 2004;23(6):230-231. Does not meet criteria for eligibility. [pmid: 15627674].
Gallacher S. Importance of vitamin D in preventing fractures. Nursing & Residential Care. 2005;7(11):504-506. Does not meet criteria for eligibility.
Gallagher JC. Metabolic effects of synthetic calcitriol (Rocaltrol) in the treatment of postmenopausal osteoporosis. Metabolism: Clinical & Experimental. 1990;39(4 Suppl 1):27-29. Does not meet criteria for eligibility. [pmid: 2325568].
Gallagher JC, Riggs BL. Action of 1,25-dihydroxyvitamin D3 on calcium balance and bone turnover and its effect on vertebral fracture rate. Metabolism: Clinical & Experimental. 1990;39(4 Suppl 1):30-34. Does not meet criteria for eligibility. [pmid: 2325569].
Gallagher JC, Bishop CW, Knutson JC, et al. Effects of increasing doses of 1 alpha-hydroxyvitamin D2 on calcium homeostasis in postmenopausal osteopenic women. Journal of Bone & Mineral Research. 1994;9(5):607-614. Does not meet criteria for eligibility. [pmid: 8053388].
Gallagher JC, Fowler SE, Detter JR, et al. Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. Journal of Clinical Endocrinology & Metabolism. 2001;86(8):3618-3628. Does not meet criteria for eligibility. [pmid: 11502787].
Garnero P, Munoz F, Borel O, et al. Vitamin D receptor gene polymorphisms are associated with the risk of fractures in postmenopausal women, independently of bone mineral density. Journal of Clinical Endocrinology & Metabolism. 2005;90(8):4829-4835. Does not meet criteria for eligibility. [pmid: 15886235].
Gau JT, Clay S, Carlsen W. Parathyroid hormone, vitamin D, and calcium intake.[comment]. JAMA. 2006;295(15):1769-1770. Does not meet criteria for eligibility. [pmid: 16622134].
Gau J-T, Barcikowski RS, Clay S, et al. Falls and supplementation of vitamin D and calcium [15]. J Am Geriatr Soc. 2006;54(6):1020-1021. Does not meet criteria for eligibility. [pmid: 16776814].
Gertner JM, Domenech M. 25-Hydroxyvitamin D levels in patients treated with high-dosage ergo- and cholecalciferol. J Clin Pathol. 1977;30(2):144-150. Does not meet criteria for eligibility. [pmid: 191473]. [pmcid: 476338].
Ghose R. Osteomalacia: Recovery of bone density [2]. N Z Med J. 2004;117(1196):2p. Does not meet criteria for eligibility.
Ghose R. Sub-clinical osteomalacia [5]. N Z Med J. 2004;117(1200):2p. Does not meet criteria for eligibility.
Ghose RR. Vitamin D deficiency and muscle weakness in the elderly [3]. N Z Med J. 2005;118(1219):1p. Does not meet criteria for eligibility.
Giangiacoma J, Gleason WA. 25-hydroxyvitamin D levels and rickets. Pediatrics. 1977;60(5):761. Does not meet criteria for eligibility. [pmid: 917648].
Gillespie W J, Avenell A, Henry D A et al. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis.[update of Cochrane Database Syst Rev. 2000;(2):CD000227; PMID: 10796331]. [Review][105 refs]. Cochrane Database Syst Rev 2001;(1):CD000227. Does not meet criteria for eligibility.
Ginty F. Vitamin D and bone health. Clin Geriatr Med. 2005;35(4):69-74. Does not meet criteria for eligibility.
Ginty F, Prentice A. Can osteoporosis be prevented with dietary strategies during adolescence?[comment]. Br J Nutr. 2004;92(1):5-6. Does not meet criteria for eligibility. [pmid: 15230983].
Giraldo Alejandro, Pino W, Garcia-Ramirez LF, et al. Vitamin D dependent rickets type II and normal vitamin D receptor cDNA sequence. A cluster in a rural area of Cauca, Colombia, with more than 200 affected children. Clin Genet. 1995;48(2):57-65. Does not meet criteria for eligibility. [pmid: 7586652].
Giunta JL. Dental changes in hypervitaminosis D. Oral Surgery Oral Medicine Oral Pathology Oral Radiology & Endodontics. 1998;85(4):410-413. Does not meet criteria for eligibility.
Givon U, Friedman E, Reiner A et al. Stress fractures in the Israeli defense forces from 1995 to 1996. Clinical Orthopaedics & Related Research 2000;(373):227–232. Does not meet criteria for eligibility.
Glendenning P. Vitamin D deficiency and multicultural Australia. Med J Aust. 2002;176(5):242-243. Does not meet criteria for eligibility. [pmid: 11999247].
Glendenning P, Vasikaran SD. Vitamin D status and redefining serum PTH reference range in the elderly.[comment]. Journal of Clinical Endocrinology & Metabolism. 2002;87(2):946-947. Does not meet criteria for eligibility. [pmid: 11836346].
Glerup H, Rytter L, Mortensen L, et al. Vitamin D deficiency among immigrant children in Denmark. Eur J Pediatr. 2004;163(45):272-273. Does not meet criteria for eligibility. [pmid: 14986127].
Glintborg D, Andersen M, Hagen C et al. Higher bone mineral density in Caucasian, hirsute patients of reproductive age. Positive correlation of testosterone levels with bone mineral density in hirsutism. Clin Endocrinol (Oxf) 2005;. 62(6):. Does not meet criteria for eligibility.
Glorieux FH. Calcitriol treatment in vitamin D-dependent and vitamin D-resistant rickets. Metabolism: Clinical & Experimental. 1990;39(4 Suppl 1):10-12. Does not meet criteria for eligibility. [pmid: 2157942].
Glorieux FH, Salle BL, Delvin EE, et al. Vitamin D metabolism in preterm infants: serum calcitriol values during the first five days of life. Eur J Pediatr. 1981;99(4):640-643. Does not meet criteria for eligibility.
Gloth FM, Alam W, Hollis B. Vitamin D vs broad spectrum phototherapy in the treatment of seasonal affective disorder. J Nutr Health Aging. 1999;3(1):5-7. Does not meet criteria for eligibility. [pmid: 10888476].
Gloth FM, Smith CE, Hollis BW, et al. Functional improvement with vitamin D replenishment in a cohort of frail, vitamin D-deficient older people. J Am Geriatr Soc. 1995;43(11):1269-1271. Does not meet criteria for eligibility. [pmid: 7594162].
Gloth FM, Tobin JD, Sherman SS, et al. Is the recommended daily allowance for vitamin D too low for the homebound elderly?. J Am Geriatr Soc. 1991;39(2):137-141. Does not meet criteria for eligibility. [pmid: 1991945].
Glowacki J, Hurwitz S, Thornhill TS, et al. Osteoporosis and vitamin-D deficiency among postmenopausal women with osteoarthritis undergoing total hip arthroplasty. Journal of Bone & Joint Surgery - American Volume. 2003;85-A(12):2371-2377. Does not meet criteria for eligibility.
Goldman JM, Wheeler MF. Vitamin D-induced hypercalcemia. Am J Med. 1987;82(6):1277. Does not meet criteria for eligibility. [pmid: 3605151].
Goldman JM, Ahn YH, Wheeler MF. Vitamin D and hypercalcemia. JAMA. 1985;254(13):1719. Does not meet criteria for eligibility. [pmid: 4032670].
Goodyer PR, Kronick JB, Jequier S, et al. Nephrocalcinosis and its relationship to treatment of hereditary rickets. Eur J Pediatr. 1987;111(5):700-704. Does not meet criteria for eligibility.
Gordon CM, Bachrach LK, Carpenter TO, et al. Bone health in children and adolescents: A Symposium at the Annual Meeting of the Pediatric Academic Societies/Lawson Wilkins Pediatric Endocrine Society, May 2003. Current Problems in Pediatric & Adolescent Health Care. 2004;34(6):226-242. Does not meet criteria for eligibility. [pmid: 15232554].
Graafmans WC, Lips P, Ooms ME, et al. The effect of vitamin D supplementation on the bone mineral density of the femoral neck is associated with vitamin D receptor genotype. Journal of Bone & Mineral Research. 1997;12(8):1241-1245. Does not meet criteria for eligibility. [pmid: 9258754].
Gravholt CH, Lauridsen AL, Brixen K, et al. Marked disproportionality in bone size and mineral, and distinct abnormalities in bone markers and calcitropic hormones in adult turner syndrome: a cross-sectional study. Journal of Clinical Endocrinology & Metabolism. 2002;87(6):2798-2808. Does not meet criteria for eligibility. [pmid: 12050253].
Greenspan SL, Schneider DL, McClung MR, et al. Alendronate improves bone mineral density in elderly women with osteoporosis residing in long-term care facilities: A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2002;136(10):742-746. Does not meet criteria for eligibility. [pmid: 12020142].
Greer FR. Vitamin D deficiency—it's more than rickets.[comment]. Eur J Pediatr. 2003;143(4):422-423. Does not meet criteria for eligibility.
Greer FR, Tsang RC. Vitamin D in human milk: is there enough?. Journal of Pediatric Gastroenterology & Nutrition. 1983;2(Suppl):1S277-S281. Does not meet criteria for eligibility.
Greer FR, Steichen JJ, Tsang RC. Effects of increased calcium, phosphorus, and vitamin D intake on bone mineralization in very low-birth-weight infants fed formulas with Polycose and medium-chain triglycerides. Eur J Pediatr. 1982;100(6):951-955. Does not meet criteria for eligibility.
Grove O, Halver B. Relief of osteoporotic backache with fluoride, calcium, and calciferol. Acta Med Scand. 1981;209(6):469-471. Does not meet criteria for eligibility. [pmid: 6455048].
Gruber HE, Gutteridge DH, Baylink DJ. Osteoporosis associated with pregnancy and lactation: bone biopsy and skeletal features in three patients. Metab Bone Dis Relat Res. 1984;5(4):159-165. Does not meet criteria for eligibility. [pmid: 6738354].
Guillemant J, Guillemant S. Acute PTH response to oral calcium load and seasonal variation of vitamin D status in healthy young adult subjects. Eur J Clin Nutr. 1996;50(7):469-472. Does not meet criteria for eligibility. [pmid: 8862484].
Guinot C, Ezzedine K, Mauger E, et al. Phototype, vitamin D status and bone mineral density among women at risk of osteoporosis. Rev Med Interne. 2006;27(5):369-374. Non-english publication. [pmid: 16563573].
Guirguis-Blake J, Phillips RL. Oral vitamin D3 decreases fracture risk in the elderly. J Fam Pract. 2003;52(6):431-435. Does not meet criteria for eligibility. [pmid: 12791218].
Gullu S, Erdogan MF, Uysal AR, et al. A potential risk for osteomalacia due to sociocultural lifestyle in Turkish women. Endocr J. 1998;45(5):675-678. Does not meet criteria for eligibility. [pmid: 10395248].
Gutteridge DH, Holzherr ML, Retallack RW, et al. A randomized trial comparing hormone replacement therapy (HRT) and HRT plus calcitriol in the treatment of postmenopausal osteoporosis with vertebral fractures: Benefit of the combination on total body and hip density. Calcif Tissue Int. 2003;73(1):33-43. Does not meet criteria for eligibility. [pmid: 14506952].
Gutteridge DH, Price RI, Kent GN, et al. Spontaneous hip fractures in fluoride-treated patients: potential causative factors. Journal of Bone & Mineral Research. 1990;5(Suppl):1S205-S215. Does not meet criteria for eligibility.
Haddad JG, Chyu KJ, Hahn TJ, et al. Serum concentrations of 25-hydroxyvitamin D in sex-linked hypophosphatemic vitamin D-resistant rickets. Journal of Laboratory & Clinical Medicine. 1973;81(1):22-27. Does not meet criteria for eligibility. [pmid: 4344923].
Haining SA, Atkins RM, Guilland-Cumming DF, et al. Vitamin D metabolites in patients with established non-union of fracture. Bone & Mineral. 1986;1(3):205-209. Does not meet criteria for eligibility. [pmid: 3509893].
Hall RT, Callenbach JC, Sheehan MB, et al. Comparison of calcium- and phosphorus-supplemented soy isolate formula with whey-predominant premature formula in very low birth weight infants. Journal of Pediatric Gastroenterology & Nutrition. 1984;3(4):571-576. Does not meet criteria for eligibility. [pmid: 6332895].
Hamoui N, Anthone G, Crookes PF. Calcium metabolism in the morbidly obese. Obes Surg. 2004;14(1):9-12. Does not meet criteria for eligibility. [pmid: 14980026].
Hampson G, Martin FC, Moffat K, et al. Effects of dietary improvement on bone metabolism in elderly underweight women with osteoporosis: a randomised controlled trial. Osteoporos Int. 2003;14(9):750-756. Does not meet criteria for eligibility. [pmid: 12904840].
Hamson C, Goh L, Sheldon P, et al. Comparative study of bone mineral density, calcium, and vitamin D status in the Gujarati and white populations of Leicester. Postgrad Med J. 2003;79(931):279-283. Does not meet criteria for eligibility. [pmid: 12782775]. [pmcid: 1742698].
Hansen MA. Assessment of age and risk factors on bone density and bone turnover in healthy premenopausal women.[see comment]. Osteoporos Int. 1994;4(3):123-128. Does not meet criteria for eligibility. [pmid: 8069050].
Harada A, Matsui Y, Mizuno M, et al. Japanese orthopedists' interests in prevention of fractures in the elderly from falls. Osteoporos Int. 2004;15(7):560-566. Does not meet criteria for eligibility. [pmid: 15067499].
Harinarayan CV. What's in a name—25(OH)D or 25(OH)D3?[comment]. Natl Med J India. 2004;17(2):114-115. Does not meet criteria for eligibility. [pmid: 15141611].
Harinarayan CV, Ramalakshmi T, Venkataprasad U. High prevalence of low dietary calcium and low vitamin D status in healthy south Indians. Asia Pac J Clin Nutr. 2004;13(4):359-364. Does not meet criteria for eligibility. [pmid: 15563441].
Harju EJ, Heikinheimo RJ, Haavisto MU, et al. Prevention of bone fractures by annual intramuscular injection of ergocalciferol in the aged [Abstract]. Br J Surg. 1991;78(9):1145. Does not meet criteria for eligibility.
Harju E, Punnonen R, Tuimala R, et al. Vitamin D and calcitonin treatment in patients with femoral neck fracture: a prospective controlled clinical study. J Int Med Res. 1989;17(3):226-242. Does not meet criteria for eligibility. [pmid: 2548905].
Harju E, Sotaniemi E, Puranen J, et al. High incidence of low serum vitamin D concentration in patients with hip fracture. Archives of Orthopaedic & Traumatic Surgery. 1985;103(6):408-416. Does not meet criteria for eligibility.
Harrington M, Bennett T, Jakobsen J, et al. The effect of a high-protein, high-sodium diet on calcium and bone metabolism in postmenopausal women and its interaction with vitamin D receptor genotype. Br J Nutr. 2004;91(1):41-51. Does not meet criteria for eligibility. [pmid: 14748937].
Harrison HE, Lifshitz F, Blizzard RM. Comparison between crystalline dihydrotachysterol and calciferol in patients requiring pharmacologic vitamin D therapy. N Engl J Med. 1967;276(16):894-900. Does not meet criteria for eligibility. [pmid: 5297643].
Hashemipour S, Larijani B, Adibi H, et al. The status of biochemical parameters in varying degrees of vitamin D deficiency. Journal of Bone & Mineral Metabolism. 2006;24(3):213-218. Does not meet criteria for eligibility. [pmid: 16622734].
Hathcock J. Tolerable upper intake level of vitamin D.[comment]. Am J Clin Nutr. 2001;74(6):864-865. Does not meet criteria for eligibility. [pmid: 11722972].
Heaney RP. Functional indices of vitamin D status and ramifications of vitamin D deficiency. [Review] [27 refs]. Am J Clin Nutr. 2004;80(6 Suppl):1706S-1709S. Does not meet criteria for eligibility. [pmid: 15585791].
Heaney RP. Lessons for nutritional science from vitamin D.[comment]. Am J Clin Nutr. 1999;69(5):825-826. Does not meet criteria for eligibility. [pmid: 10232617].
Heaney RP. Constructive interactions among nutrients and bone-active pharmacologic agents with principal emphasis on calcium, phosphorus, vitamin D and protein. J Am Coll Nutr. 2001;20(5 Supplement):2001-409S. Does not meet criteria for eligibility.
Heaney RP. Serum 25-hydroxyvitamin D and parathyroid hormone exhibit threshold behavior.[see comment]. J Endocrinol Invest. 2005;28(2):180-182. Does not meet criteria for eligibility. [pmid: 15887867].
Heldenberg D, Tenenbaum G, Weisman Y. Effect of iron on serum 25-hydroxyvitamin D and 24,25-dihydroxyvitamin D concentrations. Am J Clin Nutr. 1992;56(3):533-536. Does not meet criteria for eligibility. [pmid: 1503065].
Henriksen C, Helland IB, Ronnestad A, et al. Fat-soluble vitamins in breast-fed preterm and term infants. Eur J Clin Nutr. 2006;60(6):756-762. Does not meet criteria for eligibility. [pmid: 16452918].
Hesse V. A start with vitamin D prophylaxis. Gynakol Prax 2005;. 29(2):. Does not meet criteria for eligibility.
Heubi JE, Hollis BW, Specker B, et al. Bone disease in chronic childhood cholestasis. I. Vitamin D absorption and metabolism. J Gastroenterol Hepatol. 1989;9(2):258-264. Does not meet criteria for eligibility.
Hilgenfeld MS, Simon S, Blowey D, et al. Lack of seasonal variations in urinary calcium/creatinine ratio in school-age children. Pediatr Nephrol. 2004;19(10):1153-1155. Does not meet criteria for eligibility. [pmid: 15309603].
Hill TR, O'Brien MM, Lamberg-Allardt C, et al. Vitamin D status of 51–75-year-old Irish women: Its determinants and impact on biochemical indices of bone turnover. Public Health Nutr. 2006;9(2):225-233. Does not meet criteria for eligibility. [pmid: 16571177].
Hill T, Collins A, O'Brien M, et al. Vitamin D intake and status in Irish postmenopausal women. Eur J Clin Nutr. 2005;59(3):404-410. Does not meet criteria for eligibility. [pmid: 15674302].
Hillman LS, Hoff N, Salmons S, et al. Mineral homeostasis in very premature infants: serial evaluation of serum 25-hydroxyvitamin D, serum minerals, and bone mineralization. Eur J Pediatr. 1985;106(6):970-980. Does not meet criteria for eligibility.
Hillman LS, Hollis B, Salmons S, et al. Absorption, dosage, and effect on mineral homeostasis of 25-hydroxycholecalciferol in premature infants: comparison with 400 and 800 IU vitamin D2 supplementation. Eur J Pediatr. 1985;106(6):981-989. Does not meet criteria for eligibility.
Hillman L, Sateesha S, Haussler M, et al. Control of mineral homeostasis during lactation: interrelationships of 25-hydroxyvitamin D, 24,25-dihydroxyvitamin D, 1,25-dihydroxyvitamin D, parathyroid hormone, calcitonin, prolactin, and estradiol. American Journal of Obstetrics & Gynecology. 1981;139(4):471-476. Does not meet criteria for eligibility. [pmid: 6970522].
Hirani V, Primatesta P. Vitamin D concentrations among people aged 65 years and over living in private households and institutions in England: population survey. Age Ageing. 2005;34(5):485-491. Does not meet criteria for eligibility. [pmid: 16043444].
Hirano T, Janakiraman N, Rosenthal IM. Vitamin D poisoning: from ingestion of concentrated vitamin D used to fortify milk. IMJ - Illinois Medical Journal. 1977;151(6):418-420. Does not meet criteria for eligibility. [pmid: 17581].
Hitz MF, Eskildsen PC, Jensen JB. Bioavailability of calcium: comparison of calcium carbonate and milk and the effect of vitamin D, age, and sex using 24-hour urine calcium as a method. Calcif Tissue Int. 2005;77(6):361-366. Does not meet criteria for eligibility. [pmid: 16362456].
Hochwald O, Harman-Boehm I, Castel H. Hypovitaminosis D among inpatients in a sunny country.[see comment]. Israel Medical Association Journal: Imaj. 2004;6(2):82-87. Does not meet criteria for eligibility.
Hock AD. Divalent cations, hormones, psyche and soma: four case reports. Journal of Chronic Fatigue Syndrome. 2000;6(34):117-131. Does not meet criteria for eligibility.
Hoff N, Haddad J, Teitelbaum S, et al. Serum concentrations of 25-hydroxyvitamin D in rickets of extremely premature infants. Eur J Pediatr. 1979;94(3):460-466. Does not meet criteria for eligibility.
Holcomb S S. Boning up on osteoporosis. Nursing Made Incredibly Easy! 2005;3(2):6–12, 14. Does not meet criteria for eligibility.
Holick MF. Sunlight and vitamin D for bone health and prevention of autoimmune diseases, cancers, and cardiovascular disease. [Review] [129 refs]. Am J Clin Nutr. 2004;80(6 Suppl):1678S-1688S. Does not meet criteria for eligibility. [pmid: 15585788].
Holick MF. Vitamin D: importance in the prevention of cancers, type 1 diabetes, heart disease, and osteoporosis.[erratum appears in Am J Clin Nutr. 2004 May;79(5):890]. [Review] [74 refs]. Am J Clin Nutr. 2004;79(3):362-371. Does not meet criteria for eligibility. [pmid: 14985208].
Holick MF. Photosynthesis of vitamin D in the skin: effect of environmental and life-style variables. Fed Proc. 1987;46(5):1876-1882. Does not meet criteria for eligibility. [pmid: 3030826].
Holick MF. Calcium and vitamin D in human health. Ann Nestle [Fr]. 2002;60(3):83-93. Does not meet criteria for eligibility.
Holick MF. The influence of vitamin D on bone health across the life cycle. Br J Nutr. 2005;135(11):2726S-2727S. Does not meet criteria for eligibility.
Hollis BW. Circulating 25-hydroxyvitamin D levels indicative of vitamin D sufficiency: Implications for establishing a new effective dietary intake recommendation for vitamin D. Br J Nutr. 2005;135(2):317-322. Does not meet criteria for eligibility.
Hollis B W, Frank N E. Quantitation of vitamin D2, vitamin D3, 25-hydroxyvitamin D2, and 25-hydroxyvitamin D3 in human milk. Methods Enzymol 1986;123167–176. Does not meet criteria for eligibility.
Hollis BW, Wagner CL. Assessment of dietary vitamin D requirements during pregnancy and lactation. [Review] [115 refs]. Am J Clin Nutr. 2004;79(5):717-726. Does not meet criteria for eligibility. [pmid: 15113709].
Hoogenboezem T, Degenhart HJ, de Muinck, et al. Vitamin D metabolism in breast-fed infants and their mothers. Pediatr Res. 1989;25(6):623-628. Does not meet criteria for eligibility. [pmid: 2740153].
Horani MH, Morley JE. Hormonal fountains of youth. Clin Geriatr Med. 2004;20(2):275-292. Does not meet criteria for eligibility. [pmid: 15182882].
Hordon LD, Peacock M. Vitamin D metabolism in women with femoral neck fracture. Bone & Mineral. 1987;2(5):413-426. Does not meet criteria for eligibility. [pmid: 2851340].
Horowitz S. Natural, active approaches to osteoporosis prevention and treatment. Alternative & Complementary Therapies. 2004;10(3):125-130. Does not meet criteria for eligibility.
Hossain M. Vitamin-D intoxication during treatment of hypoparathyroidism. Lancet. 1970;1(7657):1149-1151. Does not meet criteria for eligibility. [pmid: 4192101].
Hough S. Osteoporosis Clinical Guideline. South African Medical Association—Osteoporosis Working Group. S Afr Med J 2000;Suid-Afrikaanse Tydskrif Vir Geneeskunde. 90(9 Pt 2):907–944. Does not meet criteria for eligibility.
Humphrey B, Sheehy R. Are residents in licensed residential centres at increased risk of vitamin D deficiency?. Geriaction. 2000;18(2):7-11. Does not meet criteria for eligibility.
Iannuzzi-Sucich M, Prestwood KM, Kenny AM. Prevalence of sarcopenia and predictors of skeletal muscle mass in healthy, older men and women.[see comment]. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2002;57(12):M772-M777. Does not meet criteria for eligibility.
Ingemansson SG, Hugosson CH, Woodhouse NJ. Vitamin D deficiency and hyperparathyroidism with severe bone disease. World J Surg. 1988;12(4):517-521. Does not meet criteria for eligibility. [pmid: 3420934].
Inoue S, Igarashi M, Karube S, et al. Vitamin D3 metabolism in idiopathic osteonecrosis of femoral head. Nippon Seikeigeka Gakkai Zasshi - Journal of the Japanese Orthopaedic Association. 1987;61(6):659-666. Does not meet criteria for eligibility.
Iqbal SJ, Featherstone S, Kaddam IM, et al. Family screening is effective in picking up undiagnosed Asian vitamin D deficient subjects. Journal of Human Nutrition & Dietetics. 2001;14(5):371-376. Does not meet criteria for eligibility. [pmid: 11906578].
Iqbal SJ, Taylor WH, Fraher LJ, et al. Glutethimide and circulating 1,25-dihydroxyvitamin D in vitamin D intoxication. BMJ. 1988;297(6653):902-903. Does not meet criteria for eligibility. [pmid: 3140973]. [pmcid: 1834449].
Irnell L. Metastatic calcification of soft tissue on overdosage of vitamin D. Acta Med Scand. 1969;185(3):147-152. Does not meet criteria for eligibility. [pmid: 5306972].
Ishikawa T, Kawai K, Kanayama M, et al. Increased serum creatine kinase due to hypocalcemia in vitamin D deficiency. Pediatr Neurol. 1987;3(1):37-39. Does not meet criteria for eligibility. [pmid: 3508046].
Islam MZ, Akhtaruzzaman M, Lamberg-Allardt C. Hypovitaminosis D is common in both veiled and nonveiled Bangladeshi women. Asia Pac J Clin Nutr. 2006;15(1):81-87. Does not meet criteria for eligibility. [pmid: 16500882].
Islam MZ, Lamberg-Allardt C, Karkkainen M, et al. Vitamin D deficiency: a concern in premenopausal Bangladeshi women of two socio-economic groups in rural and urban region. Eur J Clin Nutr. 2002;56(1):51-56. Does not meet criteria for eligibility. [pmid: 11840180].
Ismail F, Epstein S, Pacifici R, et al. Serum bone gla protein (BGP) and other markers of bone mineral metabolism in postmenopausal osteoporosis.[erratum appears in Calcif Tissue Int 1987 Feb;40(2):117]. Calcif Tissue Int. 1986;39(4):230-233. Does not meet criteria for eligibility. [pmid: 3098385].
Ittner J, Dambacher MA, Muff R, et al. Reduced parathyroid hormone response to peroral phosphate in osteoporotic patients. Mineral & Electrolyte Metabolism. 1986;12(3):199-203. Does not meet criteria for eligibility. [pmid: 3014300].
Jackson JA, Kleerekoper M, Parfitt AM, et al. Bone histomorphometry in hypogonadal and eugonadal men with spinal osteoporosis. Journal of Clinical Endocrinology & Metabolism. 1987;65(1):53-58. Does not meet criteria for eligibility. [pmid: 3584399].
Jackson JA, Riggs MW, Spiekerman AM. Testosterone deficiency as a risk factor for hip fractures in men: a case-control study. Am J Med Sci. 1992;304(1):4-8. Does not meet criteria for eligibility. [pmid: 1642253].
Jansen TL, Janssen M, de Jong AJ. Severe hypercalcaemia syndrome with daily low-dose vitamin D supplementation. Br J Rheumatol. 1997;36(6):712-713. Does not meet criteria for eligibility. [pmid: 9236691].
Janssen HCJ, Samson MM, Verhaar HJ. Vitamin D deficiency, muscle function, and falls in elderly people. Am J Clin Nutr. 2002;75(4):611-615. Does not meet criteria for eligibility. [pmid: 11916748].
Jevon M, Hirayama T, Brown MA, et al. Osteoclast formation from circulating precursors in osteoporosis. Scand J Rheumatol. 2003;32(2):95-100. Does not meet criteria for eligibility. [pmid: 12737328].
Jibani M, Hodges NH. Prolonged hypercalcaemia after industrial exposure to vitamin D3. British Medical Journal Clinical Research Ed. 1985;290(6470):748-749. Does not meet criteria for eligibility. [pmid: 2982456]. [pmcid: 1418526].
Johansen A, Stone MD, O'Mahony MS, et al. Reliability of parathyroid hormone measurements in the period immediately following hip fracture. Age & Ageing. 1997;26(3):175-178. Does not meet criteria for eligibility. [pmid: 9223711].
Johnell O. Review: vitamin D plus calcium, but not vitamin D alone, prevents osteoporotic fractures in older persons. ACP J Club. 2006;144(1):14. Does not meet criteria for eligibility. [pmid: 16388563].
Judge JO, Kenny A. Vitamin D and quadriceps exercise - Got milk? Got a chair?. J Am Geriatr Soc. 2003;51(3):427-428. Does not meet criteria for eligibility. [pmid: 12588591].
Kanis JA, McCloskey EV, de Takats D, et al. Treatment of osteoporosis with vitamin D. Osteoporos Int. 1997;7(Suppl 3):S140-S146. Does not meet criteria for eligibility. [pmid: 9536320].
Kantorovich V, Gacad MA, Seeger LL, et al. Bone mineral density increases with vitamin D repletion in patients with coexistent vitamin D insufficiency and primary hyperparathyroidism. Journal of Clinical Endocrinology & Metabolism. 2000;85(10):3541-3543. Does not meet criteria for eligibility. [pmid: 11061498].
Kaplan B, Hirsch M. Current approach to fracture prevention in postmenopausal osteoporosis. Clinical & Experimental Obstetrics & Gynecology. 2004;31(4):251-255. Does not meet criteria for eligibility.
Karadavut KI, Gokce Kutsal Y, Basaran A, et al. Analysis of the clinical, biochemical and risk factors of presenil osteoporotic men. Journal of Rheumatology & Medical Rehabilitation. 2003;14(1):9-15. Non-english publication.
Karkoszka H, Chudek J, Strzelczyk P, et al. Does the vitamin D receptor genotype predict bone mineral loss in haemodialysed patients?. Nephrology Dialysis Transplantation. 1998;13(8):2077-2080. Does not meet criteria for eligibility.
Karlsson MK, Gerdhem P, Ahlborg HG. The prevention of osteoporotic fractures. Journal of Bone & Joint Surgery - British Volume. 2005;87(10):1320-1327. Does not meet criteria for eligibility. [pmid: 16189301].
Kawaguchi M, Mitsuhashi Y, Kondo S. Iatrogenic hypercalcemia due to vitamin D3 ointment (1,24(OH)2D3) combined with thiazide diuretics in a case of psoriasis. Australas J Dermatol. 2003;30(11):801-804. Does not meet criteria for eligibility.
KD W. Maternal vitamin D status during pregnancy and childhood bone mass at age 9 years: A longitudinal study: Commentary. Obstet Gynecol Surv. 2006;61(5):305-307. Does not meet criteria for eligibility.
Keddie K M. Severe depressive illness in the context of hypervitaminosis D. Br J Psychiatry Suppl 1987;150394–396. Does not meet criteria for eligibility.
Keiver K, Ellis L, Anzarut A, et al. Effect of prenatal ethanol exposure on fetal calcium metabolism. Alcoholism: Clinical & Experimental Research. 1997;21(9):1612-1618. Does not meet criteria for eligibility.
Kemppainen T, Kroger H, Janatuinen E, et al. Osteoporosis in adult patients with celiac disease. Bone. 1999;24(3):249-255. Does not meet criteria for eligibility. [pmid: 10071918].
Kessel B. Hip fracture prevention in postmenopausal women. [Review] [84 refs]. Obstet Gynecol Surv. 2004;59(6):446-455. Does not meet criteria for eligibility. [pmid: 15167766].
Kessenich C. An approach to postmenopausal osteoporosis treatment: a case study review. [Review] [44 refs]. J Am Acad Nurse Pract. 2003;15(12):539-545. Does not meet criteria for eligibility. [pmid: 14983569].
Kien CL, Browning C, Jona J, et al. Rickets in premature infants receiving parenteral nutrition: a case report and review of the literature. Jpen: Journal of Parenteral & Enteral Nutrition. 1982;6(2):152-156. Does not meet criteria for eligibility. [pmid: 6808176].
Kikuchi K, Okamoto T, Nishino M, et al. Vitamin D-dependent rickets type II: report of three cases. J Dent Child. 1988;55(6):465-468. Does not meet criteria for eligibility.
Kimlin MG. The climatology of Vitamin D producing ultraviolet radiation over the United States. Journal of Steroid Biochemistry & Molecular Biology. 2004;89–90(15):479-483. Does not meet criteria for eligibility.
Klausen T, Breum L, Sorensen HA, et al. Plasma levels of parathyroid hormone, vitamin D, calcitonin, and calcium in association with endurance exercise. Calcif Tissue Int. 1993;52(3):205-208. Does not meet criteria for eligibility. [pmid: 8481833].
Komulainen M, Kroger H, Tuppurainen MT, et al. Identification of early postmenopausal women with no bone response to HRT: results of a five-year clinical trial. Osteoporos Int. 2000;11(3):211-218. Does not meet criteria for eligibility. [pmid: 10824236].
Koo WW, Antony G, Stevens LH. Continuous nasogastric phosphorus infusion in hypophosphatemic rickets of prematurity. Am J Dis Child. 1984;138(2):172-175. Does not meet criteria for eligibility. [pmid: 6695874].
Koo WW, Gupta JM, Nayanar VV, et al. Skeletal changes in preterm infants. Arch Dis Child. 1982;57(6):447-452. Does not meet criteria for eligibility. [pmid: 6979978]. [pmcid: 1627678].
Koo WW, Krug-Wispe S, Neylan M, et al. Effect of three levels of vitamin D intake in preterm infants receiving high mineral-containing milk. Journal of Pediatric Gastroenterology & Nutrition. 1995;21(2):182-189. Does not meet criteria for eligibility. [pmid: 7472905].
Koo WW, Sherman R, Succop P, et al. Serum vitamin D metabolites in very low birth weight infants with and without rickets and fractures.[see comment]. Eur J Pediatr. 1989;114(6):1017-1022. Does not meet criteria for eligibility.
Koo WW, Tsang RC, Steichen JJ, et al. Vitamin D requirement in infants receiving parenteral nutrition. Jpen: Journal of Parenteral & Enteral Nutrition. 1987;11(2):172-176. Does not meet criteria for eligibility. [pmid: 3108539].
Koutkia P, Chen TC, Holick MF. Vitamin D intoxication associated with an over-the-counter supplement. N Engl J Med. 2001;345(1):66-67. Does not meet criteria for eligibility. [pmid: 11439958].
Krabbe S, Christiansen C, Hummer L. Serum vitamin D metabolites are not related to growth rate, bone mineral content, or serum alkaline phosphatase in male puberty. Calcif Tissue Int. 1986;38(3):127-129. Does not meet criteria for eligibility. [pmid: 3085890].
Kragballe K, Avrach WW, Politi Y, et al. Climatotherapy at the Dead Sea stimulates vitamin D3 metabolism. Acta Derm Venereol. 1996;76(4):324-325. Does not meet criteria for eligibility. [pmid: 8869697].
Krall EA, Dawson-Hughes B. Relation of fractional 47Ca retention to season and rates of bone loss in healthy postmenopausal women. Journal of Bone & Mineral Research. 1991;6(12):1323-1329. Does not meet criteria for eligibility. [pmid: 1792943].
Kreiter Shelley R, Schwartz Robert P. Rickets resurgence in the United Kingdom: Improving antenatal management in Asians: Reply. Eur J Pediatr. 2001;139(2):338. Does not meet criteria for eligibility.
Kristensen M, Jensen M, Kudsk J, et al. Short-term effects on bone turnover of replacing milk with cola beverages: a 10-day interventional study in young men. Osteoporos Int. 2005;16(12):1803-1808. Does not meet criteria for eligibility. [pmid: 15886860].
Kroger H, Penttila IM, Alhava EM. Low serum vitamin D metabolites in women with rheumatoid arthritis. Scand J Rheumatol. 1993;22(4):172-177. Does not meet criteria for eligibility. [pmid: 8356409].
Kruger D M, Lyne E D, Kleerekoper M. Vitamin D deficiency rickets. A report on three cases. Clinical Orthopaedics & Related Research 1987;(224):277–283. Does not meet criteria for eligibility.
Kruse K, Feldmann E. Healing of rickets during vitamin D therapy despite defective vitamin D receptors in two siblings with vitamin D-dependent rickets type II. Eur J Pediatr. 1995;126(1):145-148. Does not meet criteria for eligibility.
Kubota T, Kotani T, Miyoshi Y, et al. A spectrum of clinical presentations in seven Japanese patients with vitamin D deficiency. Clinical Pediatric Endocrinology. 2006;15(1):23-28. Does not meet criteria for eligibility.
Kuehn B M. Better osteoporosis management a priority: impact predicted to soar with aging population. JAMA: Journal of the American Medical Association 2005;293(20):2453, 2457–2453, 2458. Does not meet criteria for eligibility.
Kung AW, Luk KD, Chu LW, et al. Age-related osteoporosis in Chinese: an evaluation of the response of intestinal calcium absorption and calcitropic hormones to dietary calcium deprivation.[see comment]. Am J Clin Nutr. 1998;68(6):1291-1297. Does not meet criteria for eligibility. [pmid: 9846861].
Kuno H. Vitamin D status and nonhemiplegic bone mass in patients following stroke. Kurume Med J. 1998;45(3):257-263. Does not meet criteria for eligibility. [pmid: 9787596].
Kurabayashi Takumi, Matsushita Hiroshi, Kato Nozomi, et al. Effect of vitamin D receptor and estrogen receptor gene polymorphism on the relationship between dietary calcium and bone mineral density in Japanese women. Journal of Bone & Mineral Metabolism. 2004;22(2):139-147. Does not meet criteria for eligibility. [pmid: 14999525].
Laaksonen MM, Karkkainen MU, Outila TA, et al. Vitamin D receptor gene start codon polymorphism (FokI) is associated with forearm bone mineral density and calcaneal ultrasound in Finnish adolescent boys but not in girls. Journal of Bone & Mineral Metabolism. 2004;22(5):479-485. Does not meet criteria for eligibility. [pmid: 15316869].
Laaksonen M, Karkkainen M, Outila T, et al. Vitamin D receptor gene BsmI-polymorphism in Finnish premenopausal and postmenopausal women: its association with bone mineral density, markers of bone turnover, and intestinal calcium absorption, with adjustment for lifestyle factors. Journal of Bone & Mineral Metabolism. 2002;20(6):383-390. Does not meet criteria for eligibility. [pmid: 12434167].
Ladhani S, Srinivasan L, Buchanan C, et al. Presentation of vitamin D deficiency. Arch Dis Child. 2004;89(8):781-784. Does not meet criteria for eligibility. [pmid: 15269083]. [pmcid: 1720051].
Ladizesky M, Lu Z, Oliveri B, et al. Solar ultraviolet B radiation and photoproduction of vitamin D3 in central and southern areas of Argentina. Journal of Bone & Mineral Research. 1995;10(4):545-549. Does not meet criteria for eligibility. [pmid: 7610924].
Lagman R, Walsh D. Dangerous nutrition? Calcium, vitamin D, and shark cartilage nutritional supplements and cancer-related hypercalcemia.[see comment]. Support Care Cancer. 2003;11(4):232-235. Does not meet criteria for eligibility. [pmid: 12673461].
Landin-Wilhelmsen K, Wilhelmsen L, Lappas G, et al. Serum intact parathyroid hormone in a random population sample of men and women: relationship to anthropometry, life-style factors, blood pressure, and vitamin D. Calcif Tissue Int. 1995;56(2):104-108. Does not meet criteria for eligibility. [pmid: 7736316].
Larchet M, Garabedian M, Bourdeau A, et al. Calcium metabolism in children during long-term total parenteral nutrition: the influence of calcium, phosphorus, and vitamin D intakes. Journal of Pediatric Gastroenterology & Nutrition. 1991;13(4):367-375. Does not meet criteria for eligibility. [pmid: 1779310].
Lawoyin S, Zerwekh JE, Glass K, et al. Ability of 25-hydroxyvitamin D3 therapy to augment serum 1,25- and 24,25-dihydroxyvitamin D in postmenopausal osteoporosis. Journal of Clinical Endocrinology & Metabolism. 1980;50(3):593-596. Does not meet criteria for eligibility. [pmid: 6965678].
Leape LL, Valaes T. Rickets in low birth weight infants receiving total parenteral nutrition. J Pediatr Surg. 1976;11(5):665-674. Does not meet criteria for eligibility. [pmid: 825629].
Lebrun J B, Moffatt M E, Mundy R J et al. Vitamin D deficiency in a Manitoba community. Can J Public Health 1993;Revue Canadienne de Sante Publique. 84(6):394–396. Does not meet criteria for eligibility.
Lee DC, Lee GY. The use of pamidronate for hypercalcemia secondary to acute vitamin D intoxication. Journal of Toxicology - Clinical Toxicology. 1998;36(7):719-721. Does not meet criteria for eligibility. [pmid: 9865241].
Lee PE, McElhaney JE, Dian L. Calcium and vitamin D supplementation for the prevention of fractures in postmenopausal women. Aging Health. 2006;2(2):241-243. Not obtainable at time of submission.
Lee WP, Lin LW, Yeh SH, et al. Correlations among serum calcium, vitamin D and parathyroid hormone levels in the elderly in southern Taiwan. Journal of Nursing Research: JNR. 2002;10(1):65-72. Does not meet criteria for eligibility.
Legius E, Proesmans W, Eggermont E, et al. Rickets due to dietary calcium deficiency. Eur J Pediatr. 1989;148(8):784-785. Does not meet criteria for eligibility. [pmid: 2792135].
Legroux-Gerot I, Catanzariti L, Marchandise X, et al. Bone mineral density changes in hypercalciuretic osteoporotic men treated with thiazide diuretics. Joint, Bone, Spine: Revue du Rhumatisme. 2004;71(1):51-55. Does not meet criteria for eligibility.
Leslie WD, Roe EB. Preventing falls in elderly persons.[comment]. N Engl J Med. 2003;348(18):1816-1818. Does not meet criteria for eligibility. [pmid: 12724494].
Levendoglu F, Ugurlu H, Gurbilek M, et al. Increased bone resorption in the proximal femur in patients with hemiplegia. Am J Phys Med Rehabil. 2004;83(11):835-841. Does not meet criteria for eligibility. [pmid: 15502736].
Levin M. Recent developments in antimutagenesis and anticarcinogenesis. Med Actual. 2002;38(7):495-499. Does not meet criteria for eligibility.
Ley Sarah J, Horwath Caroline C, Stewart Joanna M. Attention is needed to the high prevalence of vitamin D deficiency in our older population. N Z Med J 1999;112(1101):10, 1999-472. Does not meet criteria for eligibility.
Li T, Guo XX. Prevention of rickets and vitamin D intoxication in China.[see comment]. Acta Paediatr. 1995;84(8):940. Does not meet criteria for eligibility. [pmid: 7488822].
Libow LS, Ross F, Goldberg K. Letter: “One tablet per day” for osteoporosis: hypercalcemia. Ann Intern Med. 1974;81(1):120-121. Does not meet criteria for eligibility. [pmid: 4546211].
LICATA AA. Osteoporosis, teriparatide, and dosing of calcium and vitamin D.[comment]. N Engl J Med. 2005;352(18):1930-1931. Does not meet criteria for eligibility. [pmid: 15872215].
Liebman B. Behind the headlines. Nutrition Action Healthletter 2006;33(3):1, 3–1, 7. Does not meet criteria for eligibility.
Lilliu H, Pamphile R, Chapuy MC, et al. Calcium-vitamin D3 supplementation is cost-effective in hip fractures prevention. Maturitas. 2003;44(4):299-305. Does not meet criteria for eligibility. [pmid: 12697371].
Lim H W, Gilchrest B A, Cooper K D et al. Sunlight, tanning booths, and vitamin D. J Am Acad Dermatol 2005;. 52(5):. Does not meet criteria for eligibility.
Lim LS, Takahashi PY. Osteoporosis intervention in men with hip fracture [4]. Age & Ageing. 2004;33(5):507-508. Does not meet criteria for eligibility. [pmid: 15315922].
Lindholm TS, Nilsson OS, Elmstedt E, et al. Changes in bone histomorphometry and bone mineral during treatment of osteoporosis with 1 alpha-hydroxyvitamin D3 and calcium. Acta Vitaminol Enzymol. 1981;3(3):170-176. Does not meet criteria for eligibility. [pmid: 7347489].
Lippuner K, Zehnder HJ, Casez JP, et al. PTH-related protein is released into the mother's bloodstream during location: evidence for beneficial effects on maternal calcium-phosphate metabolism. Journal of Bone & Mineral Research. 1996;11(10):1394-1399. Does not meet criteria for eligibility. [pmid: 8889837].
Lips P. Which circulating level of 25-hydroxyvitamin D is appropriate?. [Review] [23 refs]. Journal of Steroid Biochemistry & Molecular Biology. 2004;89–90(15):611-614. Does not meet criteria for eligibility.
Lips P, Bouillon R, Jongen MJ, et al. The effect of trauma on serum concentrations of vitamin D metabolites in patients with hip fracture. Bone. 1985;6(2):63-67. Does not meet criteria for eligibility. [pmid: 2409998].
Lips P, Gramans WC, Ooms ME, et al. The effect of vitamin D supplementation on the incidence of hip fractures in elderly people [Abstract]. J Bone Miner Res. 1994;9(Suppl 1):S148-S128. Does not meet criteria for eligibility.
Livshits G, Yakovenko C, Seibel M. Substantial Genetic Effects Involved in Determination of Circulating Levels of Calciotropic Hormones in Human Pedigrees. Biochem Genet. 2003;41(910):269-289. Does not meet criteria for eligibility. [pmid: 14974678].
Lore F, Di Cairano G, Periti P, et al. Effect of the administration of 1,25-dihydroxyvitamin D3 on serum levels of 25-hydroxyvitamin D in postmenopausal osteoporosis. Calcif Tissue Int. 1982;34(6):539-541. Does not meet criteria for eligibility. [pmid: 6819073].
Loveridge Nigel, Power Jon, Reeve Jonathan, et al. Bone mineralization density and femoral neck fragility. Bone. 2004;35(4):929-941. Does not meet criteria for eligibility. [pmid: 15454100].
Lowenthal MN, Shany S. Osteomalacia in Bedouin women of the Negev. Isr J Med Sci. 1994;30(7):520-523. Does not meet criteria for eligibility. [pmid: 8050878].
Lowenthal MN, Galinsky D, Fried V, et al. Acromegaly and proximal femoral fracture in an aged person: bone histomorphometry, vitamin D metabolites and parathormone. Isr J Med Sci. 1990;26(5):280-283. Does not meet criteria for eligibility. [pmid: 2380027].
Luboshitzky R, Hardoff R. Recovery from metabolic bone disease in a girl with vitamin D deficiency rickets associated with primary hyperparathyroidism. J Pediatr Endocrinol. 1997;10(2):237-241. Does not meet criteria for eligibility.
Luft FC. Phosphate's fate made easier. J Mol Med. 2005;83(1):1-2. Does not meet criteria for eligibility. [pmid: 15645197].
Lund B, Hjorth L, Kjaer I, et al. Treatment of osteoporosis of ageing with 1alpha-hydroxycholecalciferol. Lancet. 1975;2(7946):1168-1171. Does not meet criteria for eligibility. [pmid: 53656].
Lutz J. Bone mineral, serum calcium, and dietary intakes of mother/daughter pairs. Am J Clin Nutr. 1986;44(1):99-106. Does not meet criteria for eligibility. [pmid: 3728353].
Lyles KW, Colon-Emeric C. Treating vitamin D deficiency in long-term care: It should be done yesterday, but how?. J Am Med Dir Assoc. 2004;5(6):416-417. Does not meet criteria for eligibility. [pmid: 15530183].
Lyles KW, Harrelson JM, Drezner MK. The efficacy of vitamin D2 and oral phosphorus therapy in X-linked hypophosphatemic rickets and osteomalacia. Journal of Clinical Endocrinology & Metabolism. 1982;54(2):307-315. Does not meet criteria for eligibility. [pmid: 6976353].
Lyles Kenneth W. Management of patients with vertebral compression fractures. Pharmacotherapy 2002;19(1 PART 2):Jan-24S. Does not meet criteria for eligibility.
Lyman D. Undiagnosed vitamin D deficiency in the hospitalized patient.[see comment]. [Review] [14 refs]. Am Fam Physician. 2005;71(2):299-304. Does not meet criteria for eligibility. [pmid: 15686300].
MacDonald D, Swaminathan R. Seasonal variation in 25-OH vitamin D in plasma of Hong Kong Chinese. Clin Chem. 1988;34(11):2375. Does not meet criteria for eligibility. [pmid: 3180442].
MacDonald D, Lau E, Chan EL, et al. Serum intact parathyroid hormone levels in elderly Chinese females with hip fracture. Calcif Tissue Int. 1992;51(6):412-414. Does not meet criteria for eligibility. [pmid: 1451007].
Macdonald HM, McGuigan FE, Stewart A, et al. Large-scale population-based study shows no evidence of association between common polymorphism of the VDR gene and BMD in British women. Journal of Bone & Mineral Research. 2006;21(1):151-162. Does not meet criteria for eligibility. [pmid: 16355284].
MacFarlane GD, Sackrison JL, Body JJ, et al. Hypovitaminosis D in a normal, apparently healthy urban European population. Journal of Steroid Biochemistry & Molecular Biology. 2004;89–90(15):621-622. Does not meet criteria for eligibility.
Macfarlane GJ, Palmer B, Roy D, et al. An excess of widespread pain among South Asians: Are low levels of vitamin D implicated?. Ann Rheum Dis. 2005;64(8):1217-1219. Does not meet criteria for eligibility. [pmid: 16014682]. [pmcid: 1755601].
MacLennan WJ, Hamilton JC. Low plasma-25-hydroxyvitamin D without osteomalacia. Lancet. 1978;1(8075):1210. Does not meet criteria for eligibility. [pmid: 77976].
Malabanan AO, Holick MF. Vitamin D and bone health in postmenopausal women. Journal of Women's Health. 2003;12(2):151-156. Does not meet criteria for eligibility.
Mallet E, Nguyen T, Garabedian M, et al. Circulating parathyroid hormone and dihydroxylated vitamin D metabolites after oral 25 hydroxycholecalciferol in infantile rickets. Hormone & Metabolic Research. 1982;14(9):503-504. Does not meet criteria for eligibility. [pmid: 7141385].
Mamelle N, Meunier PJ, Dusan R, et al. Risk-benefit ratio of sodium fluoride treatment in primary vertebral osteoporosis. Lancet. 1988;2(8607):361-365. Does not meet criteria for eligibility. [pmid: 2899773].
Mandla S, Jones G, Tenenhouse HS. Normal 24-hydroxylation of vitamin D metabolites in patients with vitamin D-dependency rickets type I. Structural implications for the vitamin D hydroxylases. Journal of Clinical Endocrinology & Metabolism. 1992;74(4):814-820. Does not meet criteria for eligibility. [pmid: 1548347].
Marcinowska-Suchowierska E, Lorenc R, Brzozowski R. Vitamin D deficiency in patients with chronic gastrointestinal disorders: response to UVB exposure. Mater Med Pol. 1994;26(2):59-63. Does not meet criteria for eligibility. [pmid: 7745985].
Margiloff L, Harris SS, Lee S, et al. Vitamin D status of an outpatient clinic population. Calcif Tissue Int. 2001;69(5):263-267. Does not meet criteria for eligibility. [pmid: 11768195].
Markestad T, Aksnes L, Finne PH, et al. Plasma concentrations of vitamin D metabolites in premature infants. Pediatr Res. 1984;18(3):269-272. Does not meet criteria for eligibility. [pmid: 6610164].
Markestad T, Aksnes L, Finne PH, et al. Vitamin D nutritional status of premature infants supplemented with 500 IU vitamin D2 per day. Acta Paediatr Scand. 1983;72(4):517-520. Does not meet criteria for eligibility. [pmid: 6605019].
Marshall TG. Puzzling vitamin D results.[comment]. CMAJ Canadian Medical Association Journal. 2002;167(8):849-850. Does not meet criteria for eligibility.
Martinez ME, Miguel JL, Selgas R, et al. Compensation by solar irradiation of depletion of 25(OH)D in CAPD patients. Nephron. 1986;42(3):268-269. Does not meet criteria for eligibility. [pmid: 3484810].
Martinez ME, Villa E, Vazquez Martul M, et al. Influence of calcium intake on calcitriol levels in idiopathic hypercalciuria in children. Nephron. 1993;65(1):36-39. Does not meet criteria for eligibility. [pmid: 8413788].
Masuda S, [Reprint author], Okano T et al. Changes in plasma levels of vitamin d and its metabolites in normal subjects received daily oral administration of a multivitamin preparation for 44 weeks. Vitamins (Kyoto) 1991;65(11):579–594. Does not meet criteria for eligibility.
Maurer M, Riesen W, Muser J, et al. Neutralization of Western diet inhibits bone resorption independently of K intake and reduces cortisol secretion in humans. American Journal of Physiology - Renal Fluid & Electrolyte Physiology. 2003;284(1):F32-F40. Does not meet criteria for eligibility.
Mawer EB, Arlot ME, Reeve J, et al. The relationship between serum vitamin D concentrations and in vivo tetracycline labeling of osteoid in crush fracture osteoporosis. Calcif Tissue Int. 1991;48(2):78-81. Does not meet criteria for eligibility. [pmid: 2013016].
Mawer EB, Backhouse J, Hill LF, et al. Vitamin D metabolism and parathyroid function in man. Clinical Science & Molecular Medicine. 1975;48(5):349-365. Does not meet criteria for eligibility. [pmid: 165031].
Mawer EB, Stanbury W, Robinson MJ, et al. Vitamin D nutrition and vitamin D metabolism in the premature human neonate. Clin Endocrinol (Oxf). 1986;25(6):641-649. Does not meet criteria for eligibility. [pmid: 3652468].
Maxwell JD. Seasonal variation in vitamin D. Proc Nutr Soc. 1994;53(3):533-543. Does not meet criteria for eligibility. [pmid: 7886053].
McAlindon TE, Felson DT, Zhang Y, et al. Relation of dietary intake and serum levels of vitamin D to progression of osteoarthritis of the knee among participants in the Framingham Study. Ann Intern Med. 1996;125(5):353-359. Does not meet criteria for eligibility. [pmid: 8702085].
McCarty MF. Vitamin D, parathyroid hormone, and insulin sensitivity.[comment]. Am J Clin Nutr. 2004;80(5):1451-1452. Does not meet criteria for eligibility. [pmid: 15531705].
McCarty MF, Janssen HCJP, Samson MM, et al. Vitamin D status and muscle strength [1] (multiple letters). Am J Clin Nutr. 2002;76(6):1454-1456. Does not meet criteria for eligibility. [pmid: 12450916].
McCowen C, Hey E. Plasma 25-hydroxyvitamin D and rickets in low birthweight babies. Arch Dis Child. 1983;58(6):476-477. Does not meet criteria for eligibility. [pmid: 6602591].
McGovern V. Shedding light on vitamin D deficiency in women. Environ Health Perspect. 2004;112(10):A548. Does not meet criteria for eligibility. [pmid: 15064159]. [pmcid: 1241919].
McGrath N, Singh V, Cundy T. Severe vitamin D deficiency in Auckland. N Z Med J. 1993;106(969):524-526. Does not meet criteria for eligibility. [pmid: 8183494].
McIntosh N, Livesey A, Brooke OG. Plasma 25-hydroxyvitamin D and rickets in infants of extremely low birthweight. Arch Dis Child. 1982;57(11):848-850. Does not meet criteria for eligibility. [pmid: 6983328]. [pmcid: 1628021].
McKenna MJ, Freaney R. Bone density and vitamin D intoxication.[comment]. Ann Intern Med. 1998;128(6):507-508. Does not meet criteria for eligibility. [pmid: 9499344].
McKinney J. The patient's page. Bone health facts. South Med J. 2005;98(10):1058. Does not meet criteria for eligibility. [pmid: 16295830].
Meller Y, Kestenbaum R S, Shany S et al. Parathormone, calcitonin, and vitamin D metabolites during normal fracture healing in geriatric patients. Clinical Orthopaedics & Related Research 1985;(199):272–279. Does not meet criteria for eligibility.
Meller Y, Shainkin-Kestenbaum R, Shany S et al. Parathyroid hormone, calcitonin, and vitamin D metabolites during normal fracture healing in humans. A preliminary report. Clinical Orthopaedics & Related Research 1984;(183):238–245. Does not meet criteria for eligibility.
Menczel J, Foldes J, Steinberg R et al. Alfacalcidol (alpha D3) and calcium in osteoporosis. Clinical Orthopaedics & Related Research 1994;(300):241–247. Does not meet criteria for eligibility.
Mendoza C, Ortega E, Ruiz E, et al. Calcium metabolism in post-menopausal women. Rev Esp Fisiol. 1985;41(4):447-450. Does not meet criteria for eligibility. [pmid: 3938042].
Meunier P. Prevention of hip fractures by correcting calcium and vitamin D insufficiencies in elderly people. Scandinavian Journal of Rheumatology - Supplement 1996;10375–78. Does not meet criteria for eligibility.
Meunier PJ, Roux C, Seeman E, et al. The effects of strontium ranelate on the risk of vertebral fracture in women with postmenopausal osteoporosis.[see comment]. N Engl J Med. 2004;350(5):459-468. Does not meet criteria for eligibility. [pmid: 14749454].
Meunier PJ, Sebert JL, Reginster JY, et al. Fluoride salts are no better at preventing new vertebral fractures than calcium-vitamin D in postmenopausal osteoporosis: the FAVOStudy. Osteoporos Int. 1998;8(1):4-12. Does not meet criteria for eligibility. [pmid: 9692071].
Meyer HE, Falch JA, Sogaard AJ, et al. Vitamin D deficiency and secondary hyperparathyroidism and the association with bone mineral density in persons with Pakistani and Norwegian background living in Oslo, Norway, The Oslo Health Study. Bone. 2004;35(2):412-417. Does not meet criteria for eligibility. [pmid: 15268891].
Miljkovic D, Miljkovic N, McCarty MF. Up-regulatory impact of boron on vitamin D function -. Does it reflect inhibition of 24-hydroxylase?. Med Hypotheses. 2004;63(6):1054-1056. Does not meet criteria for eligibility. [pmid: 15504575].
Miller M, Crotty M, Whitehead C, et al. Nutritional assessment and intervention in patients admitted with a femoral neck fracture: a chronicle of missed opportunities. Australian Journal of Nutrition and Dietetics. 2001;58(2):86-91. Does not meet criteria for eligibility.
Miravet L, Gueris J, Redel J, et al. Action of vitamin D metabolites on PTH secretion in man. Calcif Tissue Int. 1981;33(3):191-194. Does not meet criteria for eligibility. [pmid: 6791781].
Misselwitz J, Hesse V, Markestad T. Nephrocalcinosis, hypercalciuria and elevated serum levels of 1,25-dihydroxyvitamin D in children. Possible link to vitamin D toxicity. Acta Paediatr Scand. 1990;79(67):637-643. Does not meet criteria for eligibility. [pmid: 2386055].
Molgaard C, Michaelsen KF. Vitamin D and bone health in early life. [Review] [43 refs]. Proc Nutr Soc. 2003;62(4):823-828. Does not meet criteria for eligibility. [pmid: 15018481].
Molla AM, Al Badawi M, Hammoud MS, et al. Vitamin D status of mothers and their neonates in Kuwait. Pediatr Int. 2005;47(6):649-652. Does not meet criteria for eligibility. [pmid: 16354218].
Moniz C, Dew T, Dixon T. Prevalence of vitamin D inadequacy in osteoporotic hip fracture patients in London. Current Medical Research & Opinion. 2005;21(12):1891-1894. Does not meet criteria for eligibility. [pmid: 16368037].
Moore A. Osteoporosis — why all the fuss?. World of Irish Nursing & Midwifery. 2005;13(10):27. Does not meet criteria for eligibility.
More C, Bhattoa HP, Bettembuk P, et al. The effects of pregnancy and lactation on hormonal status and biochemical markers of bone turnover. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 2003;106(2):209-213. Does not meet criteria for eligibility.
Moya M, Beltran J, Colomer J. Therapeutic and collateral effects of 25-hydroxycholecalciferol in vitamin D deficiency. Eur J Pediatr. 1977;127(1):49-55. Does not meet criteria for eligibility. [pmid: 23950].
Moya M, Cortes E, Ballester MI, et al. Short-term polycose substitution for lactose reduces calcium absorption in healthy term babies.[see comment]. Journal of Pediatric Gastroenterology & Nutrition. 1992;14(1):57-61. Does not meet criteria for eligibility. [pmid: 1573514].
Moyad MA. The potential benefits of dietary and/or supplemental calcium and vitamin D. [Review] [71 refs]. Urol Oncol. 2003;21(5):384-391. Does not meet criteria for eligibility. [pmid: 14670550].
Moyer-Mileur L, Luetkemeier M, Boomer L, et al. Effect of physical activity on bone mineralization in premature infants. Eur J Pediatr. 1995;127(4):620-625. Does not meet criteria for eligibility.
Munro I. Derivation of tolerable upper intake levels of nutrients.[comment]. Am J Clin Nutr. 2001;74(6):865-867. Does not meet criteria for eligibility. [pmid: 11722973].
Muskiet FA, Dijck-Brouwer DA, van der V, et al. Do we really need > or = 100 microg vitamin D/d, and is it safe for all of us?[comment]. Am J Clin Nutr. 2001;74(6):862-864. Does not meet criteria for eligibility. [pmid: 11722970].
Nakamura K. Vitamin D insufficiency in Japanese populations: from the viewpoint of the prevention of osteoporosis. [Review] [41 refs]. Journal of Bone & Mineral Metabolism. 2006;24(1):1-6. Does not meet criteria for eligibility. [pmid: 16369890].
Namgung R, Tsang RC, Specker BL, et al. Reduced serum osteocalcin and 1,25-dihydroxyvitamin D concentrations and low bone mineral content in small for gestational age infants: evidence of decreased bone formation rates. Eur J Pediatr. 1993;122(2):269-275. Does not meet criteria for eligibility.
Narchi H. Case-control study of diet and sun exposure in adolescents with symptomatic rickets. Ann Trop Paediatr. 2000;20(3):217-221. Does not meet criteria for eligibility. [pmid: 11064775].
Nawawi H, Girgis SI. Serum levels of bone-specific alkaline phosphatase and procollagen type I carboxyterminal peptide in vitamin D deficiency. Southeast Asian Journal of Tropical Medicine & Public Health. 2002;33(Suppl):2124-130. Does not meet criteria for eligibility.
Neer R M. Environmental light: effects on vitamin D synthesis and calcium metabolism in humans. Ann N Y Acad Sci 1985;45314–20. Does not meet criteria for eligibility.
Nisbet JA, Eastwood JB, Colston KW, et al. Detection of osteomalacia in British Asians: a comparison of clinical score with biochemical measurements. Clin Sci. 1990;78(4):383-389. Does not meet criteria for eligibility. [pmid: 2160356].
Nishimura K, Shima M, Tsugawa N, et al. Long-term hospitalization during pregnancy is a risk factor for vitamin D deficiency in neonates.[erratum appears in J Bone Miner Metab. 2003;21(4):253]. Journal of Bone & Mineral Metabolism. 2003;21(2):103-108. Does not meet criteria for eligibility. [pmid: 12601575].
Noble JM, McGuiness M, Glendenning P. Low rate of compliance with ergocalciferol therapy in vitamin-D-deficient patients with hip fracture. Med J Aust. 2002;177(5):280. Does not meet criteria for eligibility. [pmid: 12197833].
Norman AW. Sunlight, season, skin pigmentation, vitamin D, and 25-hydroxyvitamin D: integral components of the vitamin D endocrine system.[see comment][comment]. Am J Clin Nutr. 1998;67(6):1108-1110. Does not meet criteria for eligibility. [pmid: 9625080].
Nurmi I, Kaukonen JP, Luthje P, et al. Half of the patients with an acute hip fracture suffer from hypovitaminosis D: a prospective study in southeastern Finland. Osteoporos Int. 2005;16(12):2018-2024. Does not meet criteria for eligibility. [pmid: 16133642].
Nuti R, Bianchi G, Brandi ML, et al. Superiority of alfacalcidol compared to vitamin D plus calcium in lumbar bone mineral density in postmenopausal osteoporosis. Rheumatol Int. 2006;26(5):445-453. Does not meet criteria for eligibility. [pmid: 16283320].
Nuti R, Martini G, Valenti R et al. Vitamin D status and bone turnover in women with acute hip fracture. Clinical Orthopaedics & Related Research 2004;208–213. Does not meet criteria for eligibility.
O'Dowd K J. Dietary factors, sunlight exposure, and vitamin D status among elderly nursing home residents living in the New York City area. 1990. Error in electronic citation. Not obtainable at time of submission.
O'Shea D, Carter GD. Hypovitaminosis D in medical inpatients.[comment]. N Engl J Med. 1998;339(5):345-346. Does not meet criteria for eligibility. [pmid: 9696643].
Ogle SJ, Davison JG. Vitamin D status in healthy elderly subjects in Auckland. N Z Med J. 1985;98(778):351. Does not meet criteria for eligibility. [pmid: 3858727].
Okazaki R, Matsumoto T, Harada S, et al. Erythrocytosis in hypophosphatemic rickets: irreversible complication due to nephrocalcinosis after vitamin D and phosphate therapy. Jpn J Med. 1991;30(6):545-547. Does not meet criteria for eligibility. [pmid: 1665879].
Okonofua F, Menon RK, Houlder S, et al. Calcium, vitamin D and parathyroid hormone relationships in pregnant Caucasian and Asian women and their neonates. Ann Clin Biochem. 1987;24(Pt 1):22-28. Does not meet criteria for eligibility. [pmid: 3827181].
Oliveira Steve, Aro Antonio, Sparrow David, et al. Season modifies the relationship between bone and blood lead levels: The Normative Aging Study. Arch Environ Health. 2002;57(5):466-472. Does not meet criteria for eligibility. [pmid: 12641191].
Oliveri B, Gomez Acotto C, Mautalen C. Osteomalacia in a patient with severe anorexia nervosa. Revue du Rhumatisme (English Edition). 1999;66(10):505-508. Does not meet criteria for eligibility.
Oliveri MB, Wittich A, Mautalen C, et al. Peripheral bone mass is not affected by winter vitamin D deficiency in children and young adults from Ushuaia. Calcif Tissue Int. 2000;67(3):220-224. Does not meet criteria for eligibility. [pmid: 10954776].
Orbak Z, Hatun S, Ozkan B et al. Rickets in early infancy: The characteristic features. Cocuk Sagligi Ve Hastaliklari Dergisi 2005;. 48(1):. Does not meet criteria for eligibility.
Orimo H, Shiraki M, Hayashi Y, et al. Effects of 1 alpha-hydroxyvitamin D3 on lumbar bone mineral density and vertebral fractures in patients with postmenopausal osteoporosis. Calcif Tissue Int. 1994;54(5):370-376. Does not meet criteria for eligibility. [pmid: 8062152].
Orwoll ES, McClung MR, Oviatt SK, et al. Histomorphometric effects of calcium or calcium plus 25-hydroxyvitamin D3 therapy in senile osteoporosis. Journal of Bone & Mineral Research. 1989;4(1):81-88. Does not meet criteria for eligibility. [pmid: 2718782].
Osher L, Lembach L, Brooks TS, et al. Rickets. A study with case report. J Am Podiatr Med Assoc. 1996;86(6):266-274. Does not meet criteria for eligibility. [pmid: 8699350].
Ott SM, Chesnut CH. Calcitriol treatment is not effective in postmenopausal osteoporosis.[see comment]. Ann Intern Med. 1989;110(4):267-274. Does not meet criteria for eligibility. [pmid: 2913914].
Overton TR, Basu TK. Longitudinal changes in radial bone density in older men. Eur J Clin Nutr. 1999;53(3):211-215. Does not meet criteria for eligibility. [pmid: 10201803].
Ovesen L, Andersen R, Jakobsen J. Geographical differences in vitamin D status, with particular reference to European countries. [Review] [96 refs]. Proc Nutr Soc. 2003;62(4):813-821. Does not meet criteria for eligibility. [pmid: 15018480].
Ozsoylu S. Rickets in Nigerian children.[comment]. Eur J Pediatr. 2001;138(6):955-956. Does not meet criteria for eligibility.
Ozsoylu S, Hansaoglu A. 25-hydroxycholecalciferol serum levels in breast-fed infants. Arch Dis Child. 1981;56(4):318. Does not meet criteria for eligibility. [pmid: 7247449].
Pak CY, DeLuca HF, Bartter FC, et al. Treatment of vitamin D-resistant rickets with 25-hydroxycholecalciferol. Arch Intern Med. 1972;129(6):894-899. Does not meet criteria for eligibility. [pmid: 4338211].
Palmieri GM, Pitcock JA, Brown P, et al. Effect of calcitonin and vitamin D in osteoporosis. Calcif Tissue Int. 1989;45(3):137-141. Does not meet criteria for eligibility. [pmid: 2505903].
Pan WH, Wang CY, Li LA, et al. No significant effect of calcium and vitamin D supplementation on blood pressure and calcium metabolism in elderly Chinese.[erratum appears in Chin J Physiol 1993;36(3):192]. Chin J Physiol. 1993;36(2):85-94. Does not meet criteria for eligibility. [pmid: 8198625].
Panda Dibyendu K, Miao Dengshun, Bolivar Isabel, et al. Inactivation of the 25-hydroxyvitamin D 1alpha-hydroxylase and vitamin D receptor demonstrates independent and interdependent effects of calcium and vitamin D on skeletal and mineral homeostasis. J Biol Chem. 2004;279(16):16754-16766. Does not meet criteria for eligibility. [pmid: 14739296].
Parry Nicola MA, Phillippo Michael, Reid Martin D, et al. Molybdenum-induced changes in the epiphyseal growth plate. Calcif Tissue Int. 1993;53(3):180-186. Does not meet criteria for eligibility. [pmid: 8242470].
Partanen J, Heikkinen J, Jamsa T, et al. Characteristics of lifetime factors, bone metabolism, and bone mineral density in patients with hip fracture. Journal of Bone & Mineral Metabolism. 2002;20(6):367-375. Does not meet criteria for eligibility. [pmid: 12434165].
Passeri G, Pini G, Troiano L, et al. Low vitamin D status, high bone turnover, and bone fractures in centenarians.[see comment]. Journal of Clinical Endocrinology & Metabolism. 2003;88(11):5109-5115. Does not meet criteria for eligibility. [pmid: 14602735].
Paterson CR. Hypercalcaemia in alphacalcidol therapy. Postgrad Med J. 1981;57(669):431-432. Does not meet criteria for eligibility. [pmid: 7312738]. [pmcid: 2424975].
Pattanaungkul S, Riggs BL, Yergey AL, et al. Relationship of intestinal calcium absorption to 1,25-dihydroxyvitamin D [1,25(OH)2D] levels in young versus elderly women: evidence for age-related intestinal resistance to 1,25(OH)2D action. Journal of Clinical Endocrinology & Metabolism. 2000;85(11):4023-4027. Does not meet criteria for eligibility. [pmid: 11095427].
Pawley N, Bishop NJ. Prenatal and infant predictors of bone health: the influence of vitamin D. [Review] [23 refs]. Am J Clin Nutr. 2004;80(6 Suppl):1748S-1751S. Does not meet criteria for eligibility. [pmid: 15585799].
Pazianas M, Butcher GP, Subhani JM, et al. Calcium absorption and bone mineral density in celiacs after long term treatment with gluten-free diet and adequate calcium intake. Osteoporos Int. 2005;16(1):56-63. Does not meet criteria for eligibility. [pmid: 15221205].
Peacock M, Liu G, Carey M, et al. Effect of calcium or 25OH vitamin D3 dietary supplementation on bone loss at the hip in men and women over the age of 60.[see comment]. Journal of Clinical Endocrinology & Metabolism. 2000;85(9):3011-3019. Does not meet criteria for eligibility. [pmid: 10999778].
Pedersen AN. Danish dietary recommendations for the elderly. Aging-Clinical & Experimental Research. 1993;5(2 Suppl 1):85-91. Does not meet criteria for eligibility.
Peregrin T. Expanding Vitamin D fortification: a balance between deficiency and toxicity. J Am Diet Assoc. 2002;102(9):1214-1216. Does not meet criteria for eligibility. [pmid: 12792609].
Perez-Duenas B, Cambra FJ, Vilaseca MA, et al. New approach to osteopenia in phenylketonuric patients. Acta Paediatr. 2002;91(8):899-904. Does not meet criteria for eligibility. [pmid: 12222712].
Peris P, Guanabens N, Monegal A, et al. Aetiology and presenting symptoms in male osteoporosis. Br J Rheumatol. 1995;34(10):936-941. Does not meet criteria for eligibility. [pmid: 7582699].
Petersen MM, Briggs RS, Ashby MA, et al. Parathyroid hormone and 25-hydroxyvitamin D concentrations in sick and normal elderly people. British Medical Journal Clinical Research Ed. 1983;287(6391):521-523. Does not meet criteria for eligibility. [pmid: 6411203]. [pmcid: 1548439].
Pettifor JM, Bikle Daniel D, Cavaleros Meropi, et al. Serum levels of free 1,25-dihydroxyvitamin D in vitamin D toxicity. Ann Intern Med. 1995;122(7):511-513. Does not meet criteria for eligibility. [pmid: 7872586].
Pettifor J M, Moodley G P, Hough F S et al. The effect of season and latitude on in vitro vitamin D formation by sunlight in South Africa. S Afr Med J 1996;Suid-Afrikaanse Tydskrif Vir Geneeskunde. 86(10):1270–1272. Does not meet criteria for eligibility.
Pettifor JM, Stein H, Herman A, et al. Mineral homeostasis in very low birth weight infants fed either own mother's milk or pooled pasteurized preterm milk. Journal of Pediatric Gastroenterology & Nutrition. 1986;5(2):248-253. Does not meet criteria for eligibility. [pmid: 3514833].
Pettifor John M, jmpe@chironwitsacza]. Rickets. Calcif Tissue Int 2002;70(5):398–399. Does not meet criteria for eligibility.
Pfeifer M, Minne HW. Prevention of falls and fractures in elderly persons-supplementation with vitamin D and calcium are efficacious. Dtsch Arztebl. 2006;103(3):C99-C100. Does not meet criteria for eligibility.
Pfeifer M, Begerow B, Minne HW, et al. Effects of a short-term vitamin D(3) and calcium supplementation on blood pressure and parathyroid hormone levels in elderly women. Journal of Clinical Endocrinology & Metabolism. 2001;86(4):1633-1637. Does not meet criteria for eligibility. [pmid: 11297596].
Pfeifer M, Dobnig H, Begerow B, et al. Effects of vitamin D and calcium supplementation on falls and parameters of muscle function: a prospective randomized, double-blind muliti-centre study [abstract]. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research. 2004;19(Suppl 1):S58. Does not meet criteria for eligibility.
Phillips F. Diet and bone health. Food Nutr Bull. 2004;29(2):99-110. Does not meet criteria for eligibility.
Phillips P, Lovell GA, Byth J, et al. Plasma 25-hydroxyvitamin D levels in elderly, institutionalised subjects in a sub-tropical climate. [abstract]. Aust NZ J Med Suppl. 1988;18(2 Suppl 1):193. Does not meet criteria for eligibility.
Pittard WB, Geddes KM, Sutherland SE, et al. Longitudinal changes in the bone mineral content of term and premature infants.[see comment]. Am J Dis Child. 1990;144(1):36-40. Does not meet criteria for eligibility. [pmid: 2294718].
Plotnikoff GA, Quigley JM. Prevalence of severe hypovitaminosis D in patients with persistent, nonspecific musculoskeletal pain.[see comment]. Mayo Clin Proc. 2003;78(12):1463-1470. Does not meet criteria for eligibility. [pmid: 14661675].
Pollak RD, Karmeli F, Eliakim R, et al. Femoral neck osteopenia in patients with inflammatory bowel disease. Am J Gastroenterol. 1998;93(9):1483-1490. Does not meet criteria for eligibility. [pmid: 9732930].
Porcu L, Meloni A, Casula L, et al. A novel splicing defect (IVS6+1G>T) in a patient with pseudovitamin D deficiency rickets. J Endocrinol Invest. 2002;25(6):557-560. Does not meet criteria for eligibility. [pmid: 12109629].
Porthouse J, Cockayne S, King C, et al. Randomised controlled trial of calcium and vitamin D supplementation for fracture prevention in primary care. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA. 2004;15(Suppl 2):S13. Does not meet criteria for eligibility.
Prabhala A, Garg R, Dandona P. Severe myopathy associated with vitamin D deficiency in western New York. Arch Intern Med. 2000;160(8):1199-1203. Does not meet criteria for eligibility. [pmid: 10789615].
Prentice, A., Yan, L., Jarjou, L. M., Dibba, B., Laskey, M. A., Stirling, D. M., and Fairweather-Tait, S., Vitamin D status. Does not influence the breast-milk calcium concentration of lactating mothers accustomed to a low calcium intake, Acta Paediatrica, 86(9), 1997, p.1006 – 1008. Does not meet criteria for eligibility.
Prestwood KM, Thompson DL, Kenny AM, et al. Low dose estrogen and calcium have an additive effect on bone resorption in older women. Journal of Clinical Endocrinology & Metabolism. 1999;84(1):179-183. Does not meet criteria for eligibility. [pmid: 9920080].
Price DI, Stanford LCJ, Braden DS, et al. Hypocalcemic rickets: An unusual cause of dilated cardiomyopathy. Pediatr Cardiol. 2003;24(5):510-512. Does not meet criteria for eligibility. [pmid: 14627327].
Prince Richard L, Dick Ian, Devine Amanda, et al. The Effects of Menopause and Age on Calcitropic Hormones: A Cross-Sectional Study of 655 Healthy Women Aged 35 to 90. Journal of Bone & Mineral Research. 1995;10(6):835-842. Does not meet criteria for eligibility. [pmid: 7572305].
Pugliese Michael T, Blumberg Denise L, Hludzinski Joanne, et al. Nutritional rickets in suburbia. J Am Coll Nutr. 1998;17(6):637-641. Does not meet criteria for eligibility. [pmid: 9853545].
Pun KK, Lau P, Wong FH, et al. 25-Hydroxycholecalciferol and insulin-like growth factor I are determinants of serum concentration of osteocalcin in elderly subjects with and without spinal fractures. Bone. 1990;11(6):397-400. Does not meet criteria for eligibility. [pmid: 2078433].
Puschett JB, Genel M, Rastegar A, et al. Effects of 25-hydroxycholecalciferol on urinary electrolyte excretion in hypophosphataemic rickets. Lancet. 1974;2(7886):920-922. Does not meet criteria for eligibility. [pmid: 4138190].
Puschett JB, Genel M, Rastegar A, et al. Long-term therapy of viramin D-resistant richets with 25-hydroxycholecalciferol. Clinical Pharmacology & Therapeutics. 1975;17(2):202-211. Does not meet criteria for eligibility. [pmid: 164313].
Quesada JM, Alonso J, Gonzalez J, et al. Serum beta-2 microglobulin is a marker of high bone remodelling in elderly women. Mechanisms of Ageing & Development. 1998;102(23):293-298. Does not meet criteria for eligibility. [pmid: 9720659].
Raef H, Frayha HH, El-Shaker M, et al. Recommendations for the diagnosis and management of osteoporosis: a local perspective. Ann Saudi Med. 2004;24(4):242-252. Does not meet criteria for eligibility. [pmid: 15387487].
Raiten DJ, Picciano MF. Vitamin D and health in the 21st century: bone and beyond. Executive summary. [Review] [20 refs]. Am J Clin Nutr. 2004;80(6 Suppl):1673S-1677S. Does not meet criteria for eligibility. [pmid: 15585787].
Ramakrishnan K, Holick MF. Understimation of serum 25-hydroxyvitamin d by the nichols advantage assay in patients receiving vitamin D replacement therapy [13]. Clin Chem. 2005;51(6):1074-1074. Does not meet criteria for eligibility. [pmid: 15914798].
Ranganath L, Jamal H, Jones L, et al. Value of assessing parathyroid hormone-like activity in a case of extreme hypercalcaemia. J Clin Pathol. 1998;51(3):257-258. Does not meet criteria for eligibility. [pmid: 9659276]. [pmcid: 500655].
Rapin CH, Lagier R, Boivin G, et al. Biochemical findings in blood of aged patients with femoral neck fractures: a contribution to the detection of occult osteomalacia. Calcif Tissue Int. 1982;34(5):465-469. Does not meet criteria for eligibility. [pmid: 6817895].
Rapin CH, Lagier R, Boivin G, et al. Is a certain degree of osteomalacia involved in femoral neck fractures of the elderly? Histological approach to the problem and practical applications. Z Gerontol. 1983;16(6):277-283. Does not meet criteria for eligibility. [pmid: 6666240].
Rasmussen Lone, Banke Reprint, author Hansen et al. Vitamin D: Should the supply in the Danish population be increased?. International Journal of Food Sciences & Nutrition 2000;51(3):209–215. Does not meet criteria for eligibility.
Reeve J, Abraham R, Walton J, et al. Increasing mineral density after menopause in individual lumbar vertebrae as a marker for incident degenerative disease: a pilot study for the effects of body composition and diet. Br J Rheumatol. 2004;31(10):1986-1992. Does not meet criteria for eligibility.
Reeves GD, Bachrach S, Carpenter TO, et al. Vitamin D-deficiency rickets in adopted children from the former Soviet Union: an uncommon problem with unusual clinical and biochemical features. Pediatrics. 2000;106(6):1484-1488. Does not meet criteria for eligibility. [pmid: 11099609].
Reginster JY, Frederick I, Deroisy R, et al. Parathyroid hormone plasma concentration in response to low 25-OH vitamin D circulating levels increases with age in elderly women. Osteoporos Int. 1998;8(4):390-392. Does not meet criteria for eligibility. [pmid: 10024911].
Reginster JY, Sarkar S, Zegels B, et al. Reduction in PINP, a marker of bone metabolism, with raloxifene treatment and its relationship with vertebral fracture risk. Bone. 2004;34(2):344-351. Does not meet criteria for eligibility. [pmid: 14962813].
Reginster JY, Zegels B, Lejeune E, et al. Influence of daily regimen calcium and vitamin D supplementation on parathyroid hormone secretion. Calcif Tissue Int. 2002;70(2):78-82. Does not meet criteria for eligibility. [pmid: 11870412].
Reginster J-Y. Treatment of postmenopausal osteoporosis. Br Med J. 2005;330(7496):16. Does not meet criteria for eligibility.
Renner RP, Boucher LJ, Kaufman HW. Osteoporosis in postmenopausal women. J Prosthet Dent. 1984;52(4):581-588. Does not meet criteria for eligibility. [pmid: 6594517].
Renoult-Pierre P. Calcium and vitamin D: Supplementation or pharmacological treatment. Annales d Endocrinologie 2005;. 66(2 I):. Does not meet criteria for eligibility.
Resch H, Pietschmann P, Woloszczuk W, et al. Bone mass and biochemical parameters of bone metabolism in men with spinal osteoporosis. Eur J Clin Invest. 1992;22(8):542-545. Does not meet criteria for eligibility. [pmid: 1425860].
Rettberg P, Horneck G, Zittermann A, et al. Biological dosimetry to determine the UV radiation climate inside the MIR station and its role in vitamin D biosynthesis. Adv Space Res. 1998;22(12):1643-1652. Does not meet criteria for eligibility. [pmid: 11542408].
Richardson JP. Vitamin D deficiency—the once and present epidemic.[comment]. Am Fam Physician. 2005;71(2):241-242. Does not meet criteria for eligibility. [pmid: 15686295].
Riggs BL, Seeman E, Hodgson SF, et al. Effect of the fluoride/calcium regimen on vertebral fracture occurrence in postmenopausal osteoporosis. Comparison with conventional therapy. N Engl J Med. 1982;306(8):446-450. Does not meet criteria for eligibility. [pmid: 6276746].
Ringe J D, Faber H, Fahramand P et al. Alfacalcidol versus plain vitamin D in the treatment of glucocorticoid/inflammation-induced osteoporosis. Journal of Rheumatology - Supplement 2005;7633–40. Does not meet criteria for eligibility.
Roberts NB, Holding JD, Walsh HP, et al. Serial changes in serum vitamin K1, triglyceride, cholesterol, osteocalcin and 25-hydroxyvitamin D3 in patients after hip replacement for fractured neck of femur or osteoarthritis. Eur J Clin Invest. 1996;26(1):24-29. Does not meet criteria for eligibility. [pmid: 8682151].
Robertson WC. Calcium carbonate consumption during pregnancy: An unusual cause of neonatal hypocalcemia. J Child Neurol. 2002;17(11):853-855. Does not meet criteria for eligibility. [pmid: 12585729].
Robinson MJ, Merrett AL, Tetlow VA, et al. Plasma 25-hydroxyvitamin D concentrations in preterm infants receiving oral vitamin D supplements. Arch Dis Child. 1981;56(2):144-145. Does not meet criteria for eligibility. [pmid: 6258489]. [pmcid: 1627110].
Rockell JE, Green TJ, Skeaff CM, et al. Season and ethnicity are determinants of serum 25-hydroxyvitamin D concentrations in New Zealand children aged 5–14 y. Br J Nutr. 2005;135(11):2602-2608. Does not meet criteria for eligibility.
Rosen JF, Finberg L. Vitamin D-dependent rickets: actions of parathyroid hormone and 25-hydroxycholecalciferol. Pediatr Res. 1972;6(6):552-562. Does not meet criteria for eligibility. [pmid: 4340043].
Rossouw JE, Anderson GL, Oberman A. Annals of Epidemiology: Foreword. Ann Epidemiol. 2003;13(9 SUPPL.):S1-S4. Does not meet criteria for eligibility.
Roth D E, Martz P, Yeo R et al. Are national vitamin D guidelines sufficient to maintain adequate blood levels in children?. Can J Public Health 2005;Revue Canadienne de Sante Publique. 96(6):443–449. Does not meet criteria for eligibility.
Rothacker DQ, Ellis PK. Elevated intakes of calcium and vitamin D without added calories and fat in overweight adults: A crossover study in Wisconsin. Current Therapeutic Research, Clinical & Experimental. 2002;63(8):507-512. Does not meet criteria for eligibility.
Rucker D, Allan JA, Fick GH, et al. Vitamin D insufficiency in a population of healthy western Canadians. CMAJ Canadian Medical Association Journal. 2002;166(12):1517-1524. Does not meet criteria for eligibility.
Rudman D, Rudman IW, Mattson DE, et al. Fractures in the men of a Veterans Administration Nursing Home: relation to 1,25-dihydroxyvitamin D. [Review] [42 refs]. J Am Coll Nutr. 1989;8(4):324-334. Does not meet criteria for eligibility. [pmid: 2674259].
Saha H. Calcium and vitamin D homeostasis in patients with heavy proteinuria. Clin Nephrol. 1994;41(5):290-296. Does not meet criteria for eligibility. [pmid: 8050209].
Sahota O, Dhesi JK, Allain TJ. A rationale for vitamin D prescribing in a falls clinic population (multiple letters) [4]. Age & Ageing. 2003;32(6):681-682. Does not meet criteria for eligibility. [pmid: 14600015].
Saitta Joseph C, Ott Susan M, Sherrard Donald J, et al. Metabolic bone disease in adults receiving long-term parenteral nutrition: Longitudinal study with regional densitometry and bone biopsy. Jpen: Journal of Parenteral & Enteral Nutrition. 1993;17(3):214-219. Does not meet criteria for eligibility. [pmid: 8505825].
Salamoni F, Roulet M, Gudinchet F, et al. Bone mineral content in cystic fibrosis patients: correlation with fat-free mass. Arch Dis Child. 1996;74(4):314-318. Does not meet criteria for eligibility. [pmid: 8669931]. [pmcid: 1511480].
Salle BL. Perinatal Vitamin D metabolism. Riv Ital Pediatr. 2003;29(5):315-318. Does not meet criteria for eligibility.
Salle BL, David L, Glorieux FH, et al. Early oral administration of vitamin D and its metabolites in premature neonates. Effect on mineral homeostasis. Pediatr Res. 1982;16(1):75-78. Does not meet criteria for eligibility. [pmid: 7070879].
Salle BL, Glorieux FH, Lapillone A. Vitamin D status in breastfed term babies.[comment]. Acta Paediatr. 1998;87(7):726-727. Does not meet criteria for eligibility. [pmid: 9722243].
Salle BL, Glorieux FH, Delvin EE, et al. Vitamin D metabolism in preterm infants. Serial serum calcitriol values during the first four days of life. Acta Paediatr Scand. 1983;72(2):203-206. Does not meet criteria for eligibility. [pmid: 6601357].
Salle BL, Senterre J, Glorieux FH, et al. Vitamin D metabolism in preterm infants. [Review] [32 refs]. Biol Neonate. 1987;52(Suppl):1119-130. Does not meet criteria for eligibility.
Salmen T, Heikkinen AM, Mahonen A, et al. Relation of aromatase gene polymorphism and hormone replacement therapy to serum estradiol levels, bone mineral density, and fracture risk in early postmenopausal women. Ann Med. 2003;35(4):282-288. Does not meet criteria for eligibility. [pmid: 12846271].
Salmen T, Heikkinen AM, Mahonen A, et al. Relation of androgen receptor gene polymorphism to bone mineral density and fracture risk in early postmenopausal women during a 5-year randomized hormone replacement therapy trial. Journal of Bone & Mineral Research. 2003;18(2):319-324. Does not meet criteria for eligibility. [pmid: 12568409].
Sambrook P. Vitamin D and fractures: Quo vadis?. Lancet. 2005;365(9471):07. Does not meet criteria for eligibility.
Sambrook PN, Chen CJS, March L, et al. High bone turnover is an independent predictor of mortality in the frail elderly. Journal of Bone & Mineral Research. 2006;21(4):549-555. Does not meet criteria for eligibility. [pmid: 16598375].
Sambrook PN, Chen JS, March LM, et al. Serum parathyroid hormone is associated with increased mortality independent of 25-hydroxy vitamin d status, bone mass, and renal function in the frail and very old: a cohort study. Journal of Clinical Endocrinology & Metabolism. 2004;89(11):5477-5481. Does not meet criteria for eligibility. [pmid: 15531500].
Sanchez CP. Chronotherapy of high-dose active Vitamin D(3): is evening dosing preferable?. [Review] [11 refs]. Pediatr Nephrol. 2004;19(7):722-723. Does not meet criteria for eligibility. [pmid: 15266665].
Sanchez PA, Idrisa A, Bobzom DN, et al. Calcium and vitamin D status of pregnant teenagers in Maiduguri, Nigeria. J Natl Med Assoc. 1997;89(12):805-811. Does not meet criteria for eligibility. [pmid: 9433060]. [pmcid: 2608295].
Saraux A, Valls I, Guedes C, et al. Insufficiency fractures of the sacrum in elderly subjects. Revue du Rhumatisme (English Edition). 1995;62(9):582-586. Does not meet criteria for eligibility.
Sato K, Emoto N, Toraya S, et al. Progressively increased serum 1,25-dihydroxyvitamin D2 concentration in a hypoparathyroid patient with protracted hypercalcemia due to vitamin D2 intoxication. Endocr J. 1994;41(4):329-337. Does not meet criteria for eligibility. [pmid: 8528347].
Sato Y, Asoh T, Oizumi K. High prevalence of vitamin D deficiency and reduced bone mass in elderly women with Alzheimer's disease. Bone. 1998;23(6):555-557. Does not meet criteria for eligibility. [pmid: 9855465].
Sato Y, Iwamoto J, Kanoko T, et al. Substandard studies or substandard ‘standard-of-care’ [2]. Journal of Bone & Mineral Research. 2006;21(3):492. Does not meet criteria for eligibility.
Sato Y, Kaji M, Higuchi F, et al. Changes in bone and calcium metabolism following hip fracture in elderly patients. Osteoporos Int. 2001;12(6):445-449. Does not meet criteria for eligibility. [pmid: 11446559].
Sato Y, Kaji M, Honda Y, et al. Abnormal calcium homeostasis in disabled stroke patients with low 25-hydroxyvitamin D. Bone. 2004;34(4):710-715. Does not meet criteria for eligibility. [pmid: 15050902].
Sato Y, Kanoko T, Satoh K, et al. Risk factors for hip fracture among elderly patients with Alzheimer's disease.[see comment]. J Neurol Sci. 2004;223(2):107-112. Does not meet criteria for eligibility. [pmid: 15337610].
Sato Y, Kanoko T, Satoh K, et al. Menatetrenone and vitamin D2 with calcium supplements prevent nonvertebral fracture in elderly women with Alzheimer's disease. Bone. 2005;36(1):61-68. Does not meet criteria for eligibility. [pmid: 15664003].
Sato Y, Kanoko T, Satoh K, et al. In reply [5]. Arch Intern Med. 2006;166(10):1145. Does not meet criteria for eligibility.
Sato Y, Kuno H, Kaji M, et al. Increased bone resorption during the first year after stroke. Stroke. 1998;29(7):1373-1377. Does not meet criteria for eligibility. [pmid: 9660389].
Sato Y, Oizumi K, Kuno H, et al. Effect of immobilization upon renal synthesis of 1,25-dihydroxyvitamin D in disabled elderly stroke patients. Bone. 1999;24(3):271-275. Does not meet criteria for eligibility. [pmid: 10071922].
Schleithoff SS, Zittermann A, Tenderich G, et al. Vitamin D supplementation improves cytokine profiles in patients with congestive heart failure: a double-blind, randomized, placebo-controlled trial.[see comment]. Am J Clin Nutr. 2006;83(4):754-759. Does not meet criteria for eligibility. [pmid: 16600924].
Schnoes HK, DeLuca HF. Recent progress in vitamin D metabolism and the chemistry of vitamin D metabolites. Fed Proc. 1980;39(10):2723-2729. Does not meet criteria for eligibility. [pmid: 6250910].
Schwartz GG, Hall MC, Stindt D, et al. Phase I/II study of 19-nor-1alpha-25-dihydroxyvitamin D2 (paricalcitol) in advanced, androgen-insensitive prostate cancer. Clin Cancer Res. 2005;11(24 Pt 1):8680-8685. Does not meet criteria for eligibility. [pmid: 16361554].
Schwartzman MS, Franck WA. Vitamin D toxicity complicating the treatment of senile, postmenopausal, and glucocorticoid-induced osteoporosis. Four case reports and a critical commentary on the use of vitamin D in these disorders. Am J Med. 1987;82(2):224-230. Does not meet criteria for eligibility. [pmid: 3812514].
Scragg R, Sowers M, Bell C. Serum 25-hydroxyvitamin D, diabetes, and ethnicity in the Third National Health and Nutrition Examination Survey. Diabetes Care. 2004;27(12):2813-2818. Does not meet criteria for eligibility. [pmid: 15562190].
Seelig MS. Are American children still getting an excess of vitamin D? Hyperreactive children at risk. Clin Pediatr (Phila). 1970;9(7):380-383. Does not meet criteria for eligibility. [pmid: 5468359].
Seeman E. Hot stuff - Can't get enough. Osteoporos Int. 2006;17(6):791-794. Does not meet criteria for eligibility. [pmid: 16715453].
Seftel A. Low serum levels of testosterone in men with minimal traumatic hip fractures: Commentary. Br J Urol. 2006;175(3):1054. Does not meet criteria for eligibility.
Segal E, Zinnman H, Raz B, et al. Adherence to vitamin D supplementation in elderly patients after hip fracture [6]. J Am Geriatr Soc. 2004;52(3):474-475. Does not meet criteria for eligibility. [pmid: 14962175].
Seibel Markus J, Meier Christian, Woitge Henning, et al. Seasonal variation of bone turnover?. Journal of Bone & Mineral Research. 2004;19(1):168-169. Does not meet criteria for eligibility. [pmid: 14753749].
Seikaly MG, Quigley R, Baum M. Effect of dipyridamole on serum and urinary phosphate in X-linked hypophosphatemia. Pediatr Nephrol. 2000;15(12):57-59. Does not meet criteria for eligibility. [pmid: 11095012].
Serhan E, Holland MR. Relationship of hypovitaminosis D and secondary hyperparathyroidism with bone mineral density among UK resident Indo-Asians. Ann Rheum Dis. 2002;61(5):456-458. Does not meet criteria for eligibility. [pmid: 11959772]. [pmcid: 1754097].
Seymour HM, Glendenning P. Fit for a fracture. Med J Aust. 2005;183(4):213-214. Does not meet criteria for eligibility. [pmid: 16097924].
Shahla A, Charehsaz S, Talebi R, et al. Vitamin D deficiency in young females with musculoskeletal complaints in Urmia, Northwest of Iran. Iranian Journal of Medical Sciences. 2005;30(2):88-90. Does not meet criteria for eligibility.
Sharkey JR, Giuliani C, Haines PS, et al. Summary measure of dietary musculoskeletal nutrient (calcium, vitamin D, magnesium, and phosphorus) intakes is associated with lower-extremity physical performance in homebound elderly men and women. Am J Clin Nutr. 2003;77(4):847-856. Does not meet criteria for eligibility. [pmid: 12663282].
Shea B, Wells G, Cranney A, et al. Review: Calcium supplementation has a small positive effect on bone mineral density but not fractures in postmenopausal women. Evidence Based Medicine. 2004;9(6):170. Does not meet criteria for eligibility.
Shetty KR, Ajlouni K, Rosenfled PS, et al. Protracted vitamin D intoxication. Arch Intern Med. 1975;135(7):986-988. Does not meet criteria for eligibility. [pmid: 1080406].
Shike M, Shils ME, Heller A, et al. Bone disease in prolonged parenteral nutrition: osteopenia without mineralization defect. Am J Clin Nutr. 1986;44(1):89-98. Does not meet criteria for eligibility. [pmid: 3088971].
Shiraki M, Kushida K, Yamazaki K, et al. Effects of 2 years' treatment of osteoporosis with 1 alpha-hydroxy vitamin D3 on bone mineral density and incidence of fracture: a placebo-controlled, double-blind prospective study. Endocr J. 1996;43(2):211-220. Does not meet criteria for eligibility. [pmid: 9026268].
Shiraki M, Miyagawa A, Akiguchi I, et al. Evidence of hypovitaminosis D in patients with mitral ring calcification. Jpn Heart J. 1988;29(6):801-808. Does not meet criteria for eligibility. [pmid: 3241333].
Sidwell AI, Wilkinson TJ, Hanger HC. Secondary prevention of fractures in older people: evaluation of a protocol for the investigation and treatment of osteoporosis. Intern Med J. 2004;34(3):129-132. Does not meet criteria for eligibility. [pmid: 15030462].
Silverman SL, Delmas PD, Kulkarni PM, et al. Comparison of fracture, cardiovascular event, and breast cancer rates at 3 years in postmenopausal women with osteoporosis. J Am Geriatr Soc. 2004;52(9):1543-1548. Does not meet criteria for eligibility. [pmid: 15341559].
Simonelli C. The role of vitamin D deficiency in osteoporosis and fractures. Minn Med. 2005;88(11):34-36. Does not meet criteria for eligibility. [pmid: 16475400].
Simonelli C, Weiss TW, Morancey J, et al. Prevalence of vitamin D inadequacy in a minimal trauma fracture population. Current Medical Research & Opinion. 2005;21(7):1069-1074. Does not meet criteria for eligibility. [pmid: 16004675].
Smith H, Anderson F, Raphael H, et al. Effect of annual intramuscular vitamin D supplementation on fracture risk: population-based, randomised, double-blind, placebo-controlled trial [abstract]. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA. 2004;15(Suppl 1):S8. Does not meet criteria for eligibility.
Smith RL. Calcium and vitamin D supplementation in nursing home residents. J Am Med Dir Assoc. 2003;4(2 SUPPL.):S24-S31. Does not meet criteria for eligibility.
Smith SM, Zwart SR, Block G, et al. The nutritional status of astronauts is altered after long-term space flight aboard the International Space Station. Br J Nutr. 2005;135(3):437-443. Does not meet criteria for eligibility.
Snell AP, MacLennan WJ, Hamilton J. Diet, sunlight, and 25-hydroxy vitamin D. Br Med J. 1979;1(6166):823. Does not meet criteria for eligibility. [pmid: 435824].
Snijder MB, van Dam RM, Visser M, et al. Adiposity in relation to vitamin D status and parathyroid hormone levels: a population-based study in older men and women. Journal of Clinical Endocrinology & Metabolism. 2005;90(7):4119-4123. Does not meet criteria for eligibility. [pmid: 15855256].
So K-W, Ng P-C. Treatment and prevention of neonatal osteopenia. Current Paediatrics 2005;. 15(2):. Does not meet criteria for eligibility.
Sogaard CH, Mosekilde L, Richards A, et al. Marked decrease in trabecular bone quality after five years of sodium fluoride therapy—assessed by biomechanical testing of iliac crest bone biopsies in osteoporotic patients. Bone. 1994;15(4):393-399. Does not meet criteria for eligibility. [pmid: 7917577].
Solanki T, Hyatt RH, Kemm JR, et al. Are elderly Asians in Britain at a high risk of vitamin D deficiency and osteomalacia?. Age & Ageing. 1995;24(2):103-107. Does not meet criteria for eligibility. [pmid: 7793330].
Sollitto RB, Kraemer KH, DiGiovanna JJ. Normal vitamin D levels can be maintained despite rigorous photoprotection: six years' experience with xeroderma pigmentosum.[see comment]. J Am Acad Dermatol. 1997;37(6):942-947. Does not meet criteria for eligibility. [pmid: 9418761].
Souberbielle JC, Fayol V, Sault C, et al. Assay-specific decision limits for two new automated parathyroid hormone and 25-hydroxyvitamin D assays. Clin Chem. 2005;51(2):395-400. Does not meet criteria for eligibility. [pmid: 15563480].
Souberbielle JC, Lawson-Body E, Hammadi B, et al. The use in clinical practice of parathyroid hormone normative values established in vitamin D-sufficient subjects.[see comment]. Journal of Clinical Endocrinology & Metabolism. 2003;88(8):3501-3504. Does not meet criteria for eligibility. [pmid: 12915625].
Souberbielle Jean-Claude, Reprint author, Lawson-Body Ethel et al. Authors' response: Vitamin D status and redefining serum PTH reference range in the elderly. Journal of Clinical Endocrinology & Metabolism 2002;87(2):947. Does not meet criteria for eligibility.
Sowers MR, Wallace RB, Hollis BW. The relationship of 1,25-dihydroxyvitamin D and radial bone mass. Bone & Mineral. 1990;10(2):139-148. Does not meet criteria for eligibility. [pmid: 2207393].
Spence JT, Serwint JR. Secondary prevention of vitamin D-deficiency rickets. Pediatrics. 2004;113(1 Pt 1):e70-e72. Does not meet criteria for eligibility. [pmid: 14702451].
Stamp TC, Round JM, Haddad JG. Effect of oral vitamin D, 25-hydroxycholecalciferol (25-HCC) and whole-body ultra-violet irradiation on plasma 25-HCC levels in man. Clin Sci. 1973;44(2):3P-4P. Does not meet criteria for eligibility.
Stein MS, Scherer SC, Walton SL, et al. Risk factors for secondary hyperparathyroidism in a nursing home population. Clin Endocrinol (Oxf). 1996;44(4):375-383. Does not meet criteria for eligibility. [pmid: 8706303].
Steingrimsdottir L, Gunnarsson O, Indridason OS, et al. Relationship between serum parathyroid hormone levels, vitamin D sufficiency, and calcium intake. JAMA. 2005;294(18):2336-2341. Does not meet criteria for eligibility. [pmid: 16278362].
Sterkel BB. Bone density and vitamin D intoxication.[comment]. Ann Intern Med. 1998;128(6):507. Does not meet criteria for eligibility. [pmid: 9499343].
Stevenson JC, Allen PR, Abeyasekera G, et al. Osteoporosis with hip fracture: changes in calcium regulating hormones. Eur J Clin Invest. 1986;16(5):357-360. Does not meet criteria for eligibility. [pmid: 3100302].
Stickler GB, Morgenstern BZ. Hypophosphataemic rickets: final height and clinical symptoms in adults.[see comment]. Lancet. 1989;2(8668):902-905. Does not meet criteria for eligibility. [pmid: 2571821].
Storm TL, Sorensen OH, Lund B, et al. Vitamin D metabolism in insulin-dependent diabetes mellitus. Metab Bone Dis Relat Res. 1983;5(3):107-110. Does not meet criteria for eligibility. [pmid: 6427548].
Strange RC, Hoban P, Salim A. Skin cancer and exposure to sunlight, polycyclic aromatic hydrocarbons, and arsenic. Clinics in Occupational & Environmental Medicine. 2002;2(4):803-828. Does not meet criteria for eligibility.
Summers GD. Osteoporosis in men. Radiography. 2001;7(2):119-123. Does not meet criteria for eligibility.
Swindells K, Rhodes LE. Influence of oral antioxidants on ultraviolet radiation-induced skin damage in humans. Photodermatol Photoimmunol Photomed. 2004;20(6):297-304. Does not meet criteria for eligibility. [pmid: 15533237].
Takeda E, [Reprint author], Yokota I et al. Effect of long-term treatment with massive doses of 1-alpha hydroxyvitamin d-3 on calcium phosphate balance in patients with vitamin d-dependent rickets TYPE II. Nippon Shonika Gakkai Zasshi 1990;32(1):39–43. Does not meet criteria for eligibility.
Takeda E, Takata K, Yamanaka H, et al. Vitamin D3 elicits calcium response and activates blood monocyte-derived macrophages from patients with vitamin D dependent rickets type II. FEBS Lett. 1996;396(23):157-160. Does not meet criteria for eligibility. [pmid: 8914979].
Tangpricha V, Flanagan JN, Whitlatch LW, et al. 25-hydroxyvitamin D-1alpha-hydroxylase in normal and malignant colon tissue. Lancet. 2001;357(9269):1673-1674. Does not meet criteria for eligibility. [pmid: 11425375].
Tannenbaum C, Clark J, Schwartzman K, et al. Yield of laboratory testing to identify secondary contributors to osteoporosis in otherwise healthy women.[see comment]. Journal of Clinical Endocrinology & Metabolism. 2002;87(10):4431-4437. Does not meet criteria for eligibility. [pmid: 12364413].
Tauber C, Noff D, Noff M, et al. Blood levels of active metabolites of vitamin D3 in fracture repair in humans. A preliminary report. Archives of Orthopaedic & Trauma Surgery. 1990;109(5):265-267. Does not meet criteria for eligibility. [pmid: 2271359].
Terenetskaya I. Two methods for direct assessment of the Vitamin D synthetic capacity of sunlight and artificial UV sources. Journal of Steroid Biochemistry & Molecular Biology 2004;89–90623–626. Does not meet criteria for eligibility.
Terris S. Calcium plus vitamin D and the risk of fractures.[comment]. N Engl J Med. 2006;354(21):2285-2287. Does not meet criteria for eligibility. [pmid: 16723622].
Thacher TD, Fischer PR, Pettifor JM, et al. Nutritional rickets in ichthyosis and response to calcipotriene. Pediatrics. 2004;114(1):e119-e123. Does not meet criteria for eligibility. [pmid: 15231983].
Thacher T, Glew RH, Isichei C, et al. Rickets in Nigerian children: response to calcium supplementation.[erratum appears in J Trop Pediatr 2000 Feb;46(1):62]. J Trop Pediatr. 1999;45(4):202-207. Does not meet criteria for eligibility. [pmid: 10467830].
Thiedke CC. Menopause. Clinics in Family Practice. 2002;4(4):985-1003. Does not meet criteria for eligibility.
Thomas MK, Lloyd-Jones DM, Thadhani RI, et al. Hypovitaminosis D in medical inpatients.[see comment]. N Engl J Med. 1998;338(12):777-783. Does not meet criteria for eligibility. [pmid: 9504937].
Thu BD, Schultink W, Dillon D, et al. Effect of daily and weekly micronutrient supplementation on micronutrient deficiencies and growth in young Vietnamese children. Am J Clin Nutr. 1999;69(1):80-86. Does not meet criteria for eligibility. [pmid: 9925127].
Thys-Jacobs S, Alvir MJ. Calcium-regulating hormones across the menstrual cycle: evidence of a secondary hyperparathyroidism in women with PMS. Journal of Clinical Endocrinology & Metabolism. 1995;80(7):2227-2232. Does not meet criteria for eligibility. [pmid: 7608284].
Tilyard M. Low-dose calcitriol versus calcium in established postmenopausal osteoporosis. Metabolism: Clinical & Experimental. 1990;39(4 Suppl 1):50-52. Does not meet criteria for eligibility. [pmid: 2325572].
Tilyard MW. 1,25-dihydroxyvitamin D3 (calcitriol) in the treatment of postmenopausal osteoporosis. Aktuelle Rheumatologie. 1994;19(SUPPL. 1):23-26. Does not meet criteria for eligibility.
Tiwari L, Puliyel JM. Vitamin D level in slum children of Delhi [9]. Indian Pediatr. 2004;41(10):1076-1077. Does not meet criteria for eligibility. [pmid: 15523147].
Toivonen J, Tahtela R, Laitinen K, et al. Markers of bone turnover in patients with differentiated thyroid cancer with and following withdrawal of thyroxine suppressive therapy. Eur J Endocrinol. 1998;138(6):667-673. Does not meet criteria for eligibility. [pmid: 9678534].
Torgerson DJ, Kanis JA. Cost-effectiveness of preventing hip fractures in the elderly population using vitamin D and calcium. QJM. 1995;88(2):135-139. Does not meet criteria for eligibility. [pmid: 7704564].
Torgerson D, Donaldson C, Reid D. Using economics to prioritize research: a case study of randomized trials for the prevention of hip fractures due to osteoporosis. Journal of Health Services & Research Policy. 1996;1(3):141-146. Does not meet criteria for eligibility.
Toss G, Almqvist S, Larsson L, et al. Vitamin D deficiency in welfare institutions for the aged. Acta Med Scand. 1980;208(12):87-89. Does not meet criteria for eligibility. [pmid: 7435254].
Tsai KS, Heath H, Kumar R, et al. Impaired vitamin D metabolism with aging in women. Possible role in pathogenesis of senile osteoporosis. Eur J Clin Invest. 1984;73(6):1668-1672. Does not meet criteria for eligibility.
Tucker KL, Hannan MT, Chen H, et al. Potassium, magnesium, and fruit and vegetable intakes are associated with greater bone mineral density in elderly men and women. Am J Clin Nutr. 1999;69(4):727-736. Does not meet criteria for eligibility. [pmid: 10197575].
Tuppurainen M, Heikkinen AM, Penttila I, et al. Does vitamin D3 have negative effects on serum levels of lipids? A follow-up study with a sequential combination of estradiol valerate and cyproterone acetate and/or vitamin D3. Maturitas. 1995;22(1):55-61. Does not meet criteria for eligibility. [pmid: 7666817].
Tylavsky FA, Cheng S, Lyytikainen A, et al. Strategies to improve vitamin D status in northern European children: exploring the merits of vitamin D fortification and supplementation. Br J Nutr. 2006;136(4):1130-1134. Does not meet criteria for eligibility.
Tylavsky FA, Holliday K, Danish R, et al. Fruit and vegetable intakes are an independent predictor of bone size in early pubertal children. Am J Clin Nutr. 2004;79(2):311-317. Does not meet criteria for eligibility. [pmid: 14749239].
Ubara Y, Katori H, Tagami T, et al. Severe ectopic calcification of the intestinal wall in a patient on long-term continuous ambulatory peritoneal dialysis therapy. Am J Kidney Dis. 2000;35(4):761-766. Does not meet criteria for eligibility. [pmid: 10739801].
Utiger RD. The need for more vitamin D.[comment]. N Engl J Med. 1998;338(12):828-829. Does not meet criteria for eligibility. [pmid: 9504945].
Valimaki VV, Alfthan H, Ivaska KK, et al. Serum estradiol, testosterone, and sex hormone-binding globulin as regulators of peak bone mass and bone turnover rate in young Finnish men. Journal of Clinical Endocrinology & Metabolism. 2004;89(8):3785-3789. Does not meet criteria for eligibility. [pmid: 15292305].
Valimaki VV, Alfthan H, Lehmuskallio E, et al. Risk factors for clinical stress fractures in male military recruits: a prospective cohort study. Bone. 2005;37(2):267-273. Does not meet criteria for eligibility. [pmid: 15964254].
Vasquez A. Health care for our bones: A practical nutritional approach to preventing osteoporosis. Journal of Manipulative & Physiological Therapeutics 2005;. 28(3):. Does not meet criteria for eligibility.
Vasquez A, Cannell J. Calcium and vitamin D in preventing fractures: data are not sufficient to show inefficacy.[comment]. BMJ. 2005;331(7508):108-109. Does not meet criteria for eligibility. [pmid: 16002891].
Vasudevan AR, Raju JM, Ganesh A, et al. Symptomatic hypercalcaemia due to vitamin D intoxication. J Assoc Physicians India. 1991;39(12):972. Does not meet criteria for eligibility. [pmid: 1816233].
Venning G. Recent developments in vitamin D deficiency and muscle weakness among elderly people. Br Med J. 2005;330(7490):524-526. Does not meet criteria for eligibility. [pmid: 15746134]. [pmcid: 552815].
Verge CF, Lam A, Simpson JM, et al. Effects of therapy in X-linked hypophosphatemic rickets.[see comment]. N Engl J Med. 1991;325(26):1843-1848. Does not meet criteria for eligibility. [pmid: 1660098].
Verhaar HJ, Samson MM, Jansen PA, et al. Muscle strength, functional mobility and vitamin D in older women.[see comment]. Aging-Clinical & Experimental Research. 2000;12(6):455-460. Does not meet criteria for eligibility.
Verhage AH, Cheong WK, Allard JP, et al. Harry M. Vars Research Award. Increase in lumbar spine bone mineral content in patients on long-term parenteral nutrition without vitamin D supplementation. Jpen: Journal of Parenteral & Enteral Nutrition. 1995;19(6):431-436. Does not meet criteria for eligibility. [pmid: 8748356].
Vezzoli G, Soldati L, Arcidiacono T et al. Urinary calcium is a determinant of bone mineral density in elderly men participating in the InCHIANTI study. Kidney Int 2005;. 67(5):. Does not meet criteria for eligibility.
Vieth R. Why the optimal requirement for Vitamin D3 is probably much higher than what is officially recommended for adults. [Review] [62 refs]. Journal of Steroid Biochemistry & Molecular Biology. 2004;89–90(15):575-579. Does not meet criteria for eligibility.
Waele BD, Smitz J, Willems G. Recurrent pancreatitis secondary to hypercalcemia following vitamin D poisoning. Pancreas. 1989;4(3):378-380. Does not meet criteria for eligibility. [pmid: 2471970].
Wagman RB, Marcus R. Beyond bone mineral density-navigating the laboratory assessment of patients with osteoporosis.[comment]. Journal of Clinical Endocrinology & Metabolism. 2002;87(10):4429-4430. Does not meet criteria for eligibility. [pmid: 12364412].
Wang LY, Hung HY, Hsu CH, et al. Congenital rickets—a patient report. J Pediatr Endocrinol. 1997;10(4):437-441. Does not meet criteria for eligibility.
Weaver CM, Fleet JC. Vitamin D requirements: current and future.[erratum appears in Am J Clin Nutr. 2005 Mar;81(3):729]. [Review] [36 refs]. Am J Clin Nutr. 2004;80(6 Suppl):1735S-1739S. Does not meet criteria for eligibility. [pmid: 15585797].
Wei GS, Jackson JL, Herbers JE. Ethnic disparity in the treatment of women with established low bone mass. Journal of the American Medical Womens Association. 2003;58(3):173-177. Does not meet criteria for eligibility.
Weinstock M A, Lazovich D. Tanning and vitamin D status. Tangpricha V, Turner A, Spina C et al. Tanning is associated with optimal vitamin D status (serum 25-hydroxyvitamin D concentration) and higher bone mineral density. Am J Clin Nutr 0204;80:1645–9. Am J Clin Nutr 2005;82(3):707. Does not meet criteria for eligibility.
Weinstock-Guttman B, Gallagher E, Baier M, et al. Risk of bone loss in men with multiple sclerosis. Mult Scler. 2004;10(2):170-175. Does not meet criteria for eligibility. [pmid: 15124763].
Weisman Y. Osteoporosis and vitamin D deficiency in Israel. Public Health Rev. 2000;28(14):59-65. Does not meet criteria for eligibility. [pmid: 11411278].
Weisman Y. Vitamin D deficiency rickets and osteomalacia in Israel. Israel Medical Association Journal: Imaj. 2003;5(4):289-290. Does not meet criteria for eligibility.
Weisman Y, Salama R, Harell A, et al. Serum 24,25-dihydroxyvitamin D and 25-hydroxyvitamin D concentrations in femoral neck fracture. Br Med J. 1978;2(6146):1196-1197. Does not meet criteria for eligibility. [pmid: 719347].
White D. Vitamin D prevents falls in the elderly. Evidence-Based Practice 2005;8(1):1–2, 8, 2p. Does not meet criteria for eligibility.
Willett A M. Vitamin D status and its relationship with parathyroid hormone and bone mineral status in older adolescents. Proc Nutr Soc 2005;. 64(2):. Does not meet criteria for eligibility.
Willig R, Jalovaara P. Effect of age on some blood variables relating to bone metabolism in women. Int J Surg Investig. 2000;1(6):495-502. Does not meet criteria for eligibility.
Willis MS. The health economics of calcium and vitamin D3 for the prevention of osteoporotic hip fractures in Sweden. Int J Technol Assess Health Care. 2002;18(4):791-807. Does not meet criteria for eligibility. [pmid: 12602080].
Wilz DR, Gray RW, Dominguez JH, et al. Plasma 1,25-(OH)2-vitamin D concentrations and net intestinal calcium, phosphate, and magnesium absorption in humans. Am J Clin Nutr. 1979;32(10):2052-2060. Does not meet criteria for eligibility. [pmid: 484524].
Woitge HW, Knothe A, Witte K, et al. Circaannual rhythms and interactions of vitamin D metabolites, parathyroid hormone, and biochemical markers of skeletal homeostasis: a prospective study. Journal of Bone & Mineral Research. 2000;15(12):2443-2450. Does not meet criteria for eligibility. [pmid: 11127208].
Wong PK, Spencer DG, McElduff P, et al. Secondary screening for osteoporosis in patients admitted with minimal-trauma fracture to a major teaching hospital. Intern Med J. 2003;33(11):505-510. Does not meet criteria for eligibility. [pmid: 14656253].
Wooltorton E. Too much of a good thing? Toxic effects of vitamin and mineral supplements. CMAJ: Canadian Medical Association Journal. 2003;169(1):47-48. Does not meet criteria for eligibility.
Xu L, McElduff P, D'Este C, et al. Does dietary calcium have a protective effect on bone fractures in women? A meta-analysis of observational studies.[see comment]. [Review] [45 refs]. Br J Nutr. 2004;91(4):625-634. Does not meet criteria for eligibility. [pmid: 15035690].
Yanoff LB, Parikh SJ, Spitalnik A, et al. The prevalence of hypovitaminosis D and secondary hyperparathyroidism in obese Black Americans. Clin Endocrinol (Oxf). 2006;64(5):523-529. Does not meet criteria for eligibility. [pmid: 16649971]. [pmcid: 1863008].
Yoon HK, Kim SW, Yim CH, et al. Metabolic characteristics and prevalence of osteoporosis among women in Tae-An area. J Korean Med Sci. 2001;16(3):323-327. Does not meet criteria for eligibility. [pmid: 11410694].
Yoshida T, Monkawa T, Tenenhouse HS, et al. Two novel 1alpha-hydroxylase mutations in French-Canadians with vitamin D dependency rickets type I1.[see comment]. Kidney Int. 1998;54(5):1437-1443. Does not meet criteria for eligibility. [pmid: 9844119].
Young G, Marcus R, Minkoff JR, et al. Age-related rise in parathyroid hormone in man: the use of intact and midmolecule antisera to distinguish hormone secretion from retention. Journal of Bone & Mineral Research. 1987;2(5):367-374. Does not meet criteria for eligibility. [pmid: 3455621].
Young R, May H, Murphy S, et al. Rates of bone loss in peri- and postmenopausal women: a 4 year, prospective, population-based study. Clin Sci. 1996;91(3):307-312. Does not meet criteria for eligibility. [pmid: 8869413].
Zadshir A, Tareen N, Pan D, et al. The prevalence of hypovitaminosis D among US adults: data from the NHANES III. Ethn Dis. 2005;15(4 Suppl 5):S5-101. Does not meet criteria for eligibility.
Zambrano Marlene, Nikitakis Nikolaos G, Sanchez-Quevedo M, et al. Oral and dental manifestations of vitamin D-dependent rickets type I: Report of a pediatric case. Oral Surgery, Oral Medicine, Oral Pathology, Oral Radiology, & Endodontics. 2003;95(6):705-709. Does not meet criteria for eligibility.
Zargar AH, Mithal A, Wani AI, et al. Pseudovitamin D deficiency rickets—a report from the Indian subcontinent. Postgrad Med J. 2000;76(896):369-372. Does not meet criteria for eligibility. [pmid: 10824056]. [pmcid: 1741602].
Zasloff M. Sunlight, vitamin D, and the innate immune defenses of the human skin. J Invest Dermatol. 2005;125(5):xvi-xvii. Does not meet criteria for eligibility. [pmid: 16297179].
Zeimer H. Re: Vitamin D for older people: How much, for whom and - Above all - Why? [7]. Age & Ageing. 2006;35(1):98. Does not meet criteria for eligibility. [pmid: 16364947].
Zhao DH, Xue QB, Xue Y. Serum 25-OHD levels in maternal and cord blood in Beijing, China. Acta Paediatr Scand. 1990;79(12):1240-1241. Does not meet criteria for eligibility. [pmid: 2085113].
Zimmermann B, Dorr HG, Muller W, et al. Maternal administration of high dose vitamin D3 for cerebral palsy in her child. Eur J Pediatr. 2004;163(45):279-280. Does not meet criteria for eligibility. [pmid: 14968361].
Zittermann A. Serum 25-hydroxyvitamin D response to oral vitamin D intake in children.[comment]. Am J Clin Nutr. 2003;78(3):496-497. Does not meet criteria for eligibility. [pmid: 12936937].
Zittermann A, Dembinski J, Stehle P. Low vitamin D status is associated with low cord blood levels of the immunosuppressive cytokine interleukin-10. Pediatric Allergy & Immunology. 2004;15(3):242-246. Does not meet criteria for eligibility. [pmid: 15209957].
Zofkova I, Kancheva RL. The effect of 1,25(OH)2 vitamin D3 on CD4+/CD8+ subsets of T lymphocytes in postmenopausal women. Life Sci. 1997;61(2):147-152. Does not meet criteria for eligibility. [pmid: 9217273].