# Appendix H. Additional Acknowledgments

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgment does not reflect endorsement of this report.

- Bess Dawson-Hughes, MD
- Tufts University Boston, MA, U.S.

- John A Eisman, AO, MBBS, PhD, FRACP
- University of New South Wales, Sydney, Australia

- Murray J. Favus, MD
- University of Chicago Hospitals Chicago, IL, U.S.

- Frank R. Greer, MD
- University of Wisconsin-Madison Medical School Perinatal Center, Meriter Hospital Madison, WI, U.S.

- Bruce W. Hollis, PhD
- Medical University of South Carolina Charleston, SC, U.S.

- Bonny Specker, PhD
- South Dakota State University, Brookings, SD, U.S.

- Connie M. Weaver, PhD
- Purdue University West Lafayette, IN, U.S.

- *David Atkins, MD, MPH
- Chief Medical Officer
- Center for Outcomes and Evidence Representing the Agency for Healthcare Research and Quality (AHRQ), U.S.

- *Mary Frances Picciano, PhD
- Senior Nutrition Research Scientist Representing the NIH Office of Dietary Supplements (ODS), U.S.

- *Anne L. Thurn, PhD
- Director, Evidence-Based Review Program Representing the NIH Office of Dietary Supplements (ODS), U.S.

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgement does not reflect endorsement of this report.

- Jonathan D. Adachi, MD, FRCP(C)
- Charlton Medical Centre Hamilton, ON, Canada

- David E.C. Cole, MD, PhD
- University of Toronto, Sunnybrook & Women's College Health Sciences Centre Toronto, ON, Canada

- John A Eisman, AO, MBBS, PhD, FRACP
- University of New South Wales Sydney, Australia

- Murray J. Favus, MD
- University of Chicago Hospitals Chicago, IL, U.S.

- David Feldman, MD
- Stanford University School of Medicine Stanford, CA, U.S.

- Frank R. Greer, MD
- University of Wisconsin Madison Medical School Perinatal Center, Madison, WI, U.S.

- Robert P. Heaney, M.D., F.A.C.P., F.A.C.N.
- Creighton University Medical Center Omaha, NE, U.S.

- Anthony Hodsman, MD
- University of Western Ontario St. Joseph's Health Care London, ON, Canada

- Bonny Specker, PhD
- South Dakota State University, Brookings, SD, U.S.

- Connie M. Weaver, PhD
- Purdue University West Lafayette, IN, U.S.

- David Goltzman, MD
- McGill University Royal Victoria Hospital Montreal, PQ, Canada
- Review also provided by:

- *David Atkins, MD, MPH
- Chief Medical Officer
- Center for Outcomes and Evidence Representing the Agency for Healthcare Research and Quality (AHRQ), U.S.

- *Mary Frances Picciano, PhD
- Senior Nutrition Research Scientist Representing the NIH Office of Dietary Supplements (ODS), U.S.

- *Anne L. Thurn, PhD
- Director, Evidence-Based Review Program Presenting the NIH Office of Dietary Supplements (ODS), U.S