# Appendix G. List of Unobtained Articles

## References

1) Vitamin D may prevent falls. Med Today 2004;5(7):8–9. Not obtainable at time of submission.
2) Vitamin D reduces risk of falls. Geriatrics and Aging 2004;7(6). Not obtainable at time of submission.
3) Commentary on Vitamin D3 and calcium to prevent hip fractures in elderly women [original article by Chapuy M et al appears in New Engl J Med 1992;327(23):1637–42]. AWHONN's Women's Health Nursing Scan 1993;7(3):5. Not obtainable at time of submission.
4) Lee P E, McElhaney J E, Dian L. Calcium and vitamin D supplementation for the prevention of fractures in postmenopausal women. Aging Health. 2006;2(2):241-243. Not obtainable at time of submission.
5) O'Dowd K J. Dietary factors, sunlight exposure, and vitamin D status among elderly nursing home residents living in the New York City area. 1990. Error in electronic citation. Not obtainable at time of submission.
6 Al Maatouq MA, El Desouki MI, Othman SA, et al. Prevalence of osteoporosis among postmenopausal females with diabetes mellitus. Saudi Med J. 2004;25(10):1423-1427. Not obtainable at time of submission. [pmid: 15494815].