# Appendix F. Additional Data Provided by Study Authors

The following additional data were provided:

## References

1 Chapuy MC, Pamphile R, Paris E, Kempf C, Schlichting M, Arnaud S, et al. Combined calcium and vitamin D3 supplementation in elderly women confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int. Mar. 2002;13(3):257-64. (Provided additional fracture data, and data on hypercalcemia). [pmid: 11991447].
2 Dawson-Hughes B, Harris SS, Krall EA, Dallal GE. Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. Sep 4. 1997;337(10):670-6. (Provided more detailed information on breakdown by gender for 25(OH)D and falls data). [pmid: 9278463].
3 Grant AM, Avenell A, Campbell MK, McDonald AM, MacLennan GS, McPherson GC, et al. Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. May. 2005;365(9471):1621-8. (Provided adverse event data breakdown by group). [pmid: 15885294].
4 Harwood RH, Sahota O, Gaynor K, Masud T, Hosking DJ. A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing. Jan. 2004;33(1):45-51. (Provided number of individuals with falls and fractures). [pmid: 14695863].
5 Porthouse J, Cockayne S, King C, Saxon L, Steele E, Aspray T, et al. Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. Apr 30. 2005;330(7498):1003. (Provided falls data). [pmid: 15860827]. [pmcid: 557150].
6 Dawson-Hughes B, Dallal GE, Krall EA, Harris S, Sokoll LJ, Falconer G. Effect of vitamin D supplementation on wintertime and overall bone loss in healthy postmenopausal women. Ann Intern Med. Oct 1. 1991;115(7):505-12. (Provided clarification on BMD data). [pmid: 1883119].
7 Ooms ME, Roos JC, Bezemer PD, van der Vijgh WJ, Bouter LM, Lips P. Prevention of bone loss by vitamin D supplementation in elderly women: a randomized double-blind trial. J Clin Endocrinol Metab. Apr. 1995;80(4):1052-8. (Provided BMD data). [pmid: 7714065].
8 Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ. Mar 1. 2003;326(7387):469. (Provided clarification on vitamin D assay). [pmid: 12609940]. [pmcid: 150177].