# Appendix E. Reference List - Quality Assessment of RCTs

## References

1 Ala-Houhala M. 25-Hydroxyvitamin D levels during breast-feeding with or without maternal or infantile supplementation of vitamin D. Journal of Pediatric Gastroenterology & Nutrition. 1985;4:220-6. [pmid: 3989622].
2 Ala-Houhala M, Koskinen T, Koskinen M, Visakorpi JK. Double blind study on the need for vitamin D supplementation in prepubertal children. Acta Paediatrica Scandinavica. 1988;77:89-93. [pmid: 3285637].
3 Aloia JF, Talwar SA, Pollack S, Yeh J. A randomized controlled trial of vitamin D3 supplementation in African American women. Archives of Internal Medicine. 2005;165:1618-23. [pmid: 16043680]. [pmcid: 1464166].
4 Anderson, F. H., Smith, H. E., Raphael, H. M., Crozier, S. R., and Cooper, C. Effect of annual intramuscular vitamin D_3_ supplementation on fracture risk in 9440 community-living older people: the Wessex fracture prevention trial. ASBMR 26th Annual Meeting Presentation #1220 10/5/2004. 2004.
5 Armas LA, Hollis BW, Heaney RP: Vitamin D2 is much less effective than vitamin D3 in humans. Journal of Clinical Endocrinology & Metabolism 2004; 89: 5387–91. Ref ID: 103
6 Baeksgaard L, Andersen KP, Hyldstrup L. Calcium and vitamin D supplementation increases spinal BMD in healthy, postmenopausal women. Osteoporos Int. 1998;8:255-60. [pmid: 9797910].
7 Barnes MS, Robson PJ, Bonham MP, Strain JJ, Wallace JMW. Effect of vitamin D supplementation on vitamin D status and bone turnover markers in young adults. European Journal of Clinical Nutrition. 2006;60:727-33. [pmid: 16391584].
8 Bischoff HA, Stahelin HB, Dick W, Akos R, Knecht M, Salis C, Nebiker M, Theiler R, Pfeifer M, Begerow B, Lew RA, Conzelmann M. Effects of vitamin D and calcium supplementation on falls: a randomized controlled trial. Journal of Bone & Mineral Research. 2003;18:343-51. [pmid: 12568412].
9 Brazier M, Kamel S, Lorget F, Maamer M, Tavera C, Heurtebize N, Grados F, Mathieu M, Garabedian M, Sebert JL, Fardellone P. Biological effects of supplementation with vitamin D and calcium in postmenopausal women with low bone mass receiving alendronate. Clinical Drug Investigation. 2002;22:849-57.
10 Brazier M, Grados F, Kamel S, Mathieu M, Morel A, Maamer M, Sebert JL, Fardellone P. Clinical and laboratory safety of one year's use of a combination calcium + vitamin D tablet in ambulatory elderly women with vitamin D insufficiency: results of a multicenter, randomized, double-blind, placebo-controlled study. Clinical Therapeutics. 2005;27:1885-93. [pmid: 16507374].
11 Brooke OG, Brown IR, Bone CD, Carter ND, Cleeve HJ, Maxwell JD, Robinson VP, Winder SM. Vitamin D supplements in pregnant Asian women: effects on calcium status and fetal growth. BMJ. 1980;280:751-4. [pmid: 6989438]. [pmcid: 1600591].
12 Cesur Y, Caksen H, Gundem A, Kirimi E, Odabas D. Comparison of low and high dose of vitamin D treatment in nutritional vitamin D deficiency rickets. Journal of Pediatric Endocrinology. 2003;16:1105-9.
13 Chan GM, Hoffman K, McMurry M. Effects of dairy products on bone and body composition in pubertal girls. Journal of Pediatrics. 1995;126:551-6. [pmid: 7699532].
14 Chan GM, Roberts CC, Folland D, Jackson R. Growth and bone mineralization of normal breast-fed infants and the effects of lactation on maternal bone mineral status. American Journal of Clinical Nutrition. 1982;36:438-43. [pmid: 7113949].
15 Chapuy MC, Arlot ME, Duboeuf F, Brun J, Crouzet B, Arnaud S, Delmas PD, Meunier PJ. Vitamin D3 and calcium to prevent hip fractures in the elderly women. New England Journal of Medicine. 1992;327:1637-42. [pmid: 1331788].
16 Chapuy MC, Pamphile R, Paris E, Kempf C, Schlichting M, Arnaud S, Garnero P, Meunier PJ. Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int. 2002;13:257-64. [pmid: 11991447].
17 Chee WS, Suriah AR, Chan SP, Zaitun Y, Chan YM. The effect of milk supplementation on bone mineral density in postmenopausal Chinese women in Malaysia. Osteoporos Int. 2003;14:828-34. [pmid: 12915959].
18 Chel VG, Ooms ME, Popp-Snijders C, Pavel S, Schothorst AA, Meulemans CC, Lips P. Ultraviolet irradiation corrects vitamin D deficiency and suppresses secondary hyperparathyroidism in the elderly. Journal of Bone & Mineral Research. 1998;13:1238-42. [pmid: 9718191].
19 Cooper L, Clifton-Bligh PB, Nery ML, Figtree G, Twigg S, Hibbert E, Robinson BG. Vitamin D supplementation and bone mineral density in early postmenopausal women. American Journal of Clinical Nutrition. 2003;77:1324-9. [pmid: 12716689].
20 Corless D, Dawson E, Fraser F, Ellis M, Evans SJ, Perry JD, Reisner C, Silver CP, Beer M, Boucher BJ. Do vitamin D supplements improve the physical capabilities of elderly hospital patients?. Age & Ageing. 1985;14:76-84. [pmid: 4003187].
21 Daly RM, Brown M, Bass S, Kukuljan S, Nowson C. Calcium- and vitamin D3-fortified milk reduces bone loss at clinically relevant skeletal sites in older men: a 2-year randomized controlled trial. Journal of Bone & Mineral Research. 2006;21:397-405. [pmid: 16491287].
22 Dawson-Hughes B, Dallal GE, Krall EA, Harris S, Sokoll LJ, Falconer G. Effect of vitamin D supplementation on wintertime and overall bone loss in healthy postmenopausal women. Annals of Internal Medicine. 1991;115:505-12. [pmid: 1883119].
23 Dawson-Hughes B, Harris SS, Krall EA, Dallal GE. Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. New England Journal of Medicine. 1997;337:670-6. [pmid: 9278463].
24 Bischoff-Ferrari HA, Orav EJ, wson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Archives of Internal Medicine. 2006;166:424-30. [pmid: 16505262].
25 Dawson-Hughes B, Harris SS, Krall EA, Dallal GE, Falconer G, Green CL. Rates of bone loss in postmenopausal women randomly assigned to one of two dosages of vitamin D. American Journal of Clinical Nutrition. 1995;61:1140-5. [pmid: 7733040].
26 de Jong N, Chin APM, De Groot LC, de Graaf C, Kok FJ, van Staveren WA. Functional biochemical and nutrient indices in frail elderly people are partly affected by dietary supplements but not by exercise. Journal of Nutrition. 1999;129:2028-36. [pmid: 10539780].
27 Delvin EE, Salle BL, Glorieux FH, Adeleine P, David LS. Vitamin D supplementation during pregnancy: effect on neonatal calcium homeostasis. Journal of Pediatrics. 1986;109:328-34. [pmid: 3488384].
28 Deroisy R, Collette J, Albert A, Jupsin I, Reginster JY. Administration of a supplement containing both calcium and vitamin D is more effective than calcium alone to reduce secondary hyperparathyroidism in postmenopausal women with low 25(OH)vitamin D circulating levels. Aging-Clinical & Experimental Research. 2002;14:13-7. [pmid: 12027147].
29 Deroisy R, Collette J, Chevallier T, Breuil V, Reginister JYRa. Effects of two 1-year calcium and vitamin D3 treatments on bone remodeling markers and femoral bone density in elderly women. Current Therapeutic Research. 1998;59:850-62.
30 Deroisy R, Collette J, Albert A, Leber C, Micheletti MC, Zartarian M, Reginster JY. Comparison of the short-term effects of three oral calcium-vitamin D formulations and placebo on calcium metabolism. Current Therapeutic Research. 1998;59:370-8.
31 Dhesi JK, Jackson SHD, Bearne LM, Moniz C, Hurley MV, Swift CG, Allain TJ. Vitamin D supplementation improves neuromuscular function in older people who fall. Age & Ageing. 2004;33:589-95. [pmid: 15501836].
32 Falkenbach A, Unkelbach U, Boehm BO, Regeniter A, Stein J, Seiffert U, Wendt T. Bone metabolism before and after irradiation with ultraviolet light. European Journal of Applied Physiology & Occupational Physiology. 1993;66:55-9. [pmid: 8425513].
33 Flicker L, MacInnis RJ, Stein MS, Scherer SC, Mead KE, Nowson CA, Thomas J, Lowndes C, Hopper JL, Wark JD. Should older people in residential care receive vitamin D to prevent falls? Results of a randomized trial. Journal of the American Geriatrics Society. 2005;53:1881-8. [pmid: 16274368].
34 Fuleihan GEH, Nabulsi M, Tamim H, Maalouf J, Salamoun M, Khalife H, Choucair M, Arabi A, Vieth R. Effect of vitamin D replacement on musculoskeletal parameters in school children: A randomized controlled trial. Journal of Clinical Endocrinology & Metabolism. 2006;91:405-12. [pmid: 16278262].
35 Goussous R, Song L, Dallal GE, Dawson-Hughes B. Lack of effect of calcium intake on the 25-hydroxyvitamin d response to oral vitamin D3. Journal of Clinical Endocrinology & Metabolism. 2005;90:707-11. [pmid: 15562015].
36 Graafmans WC, Ooms ME, Hofstee HM, Bezemer PD, Bouter LM, Lips P. Falls in the elderly: a prospective study of risk factors and risk profiles. American Journal of Epidemiology. 1996;143:1129-36. [pmid: 8633602].
37 Grados F, Brazier M, Kamel S, Mathieu M, Hurtebize N, Maamer M, Garabedian M, Sebert JL, Fardellone P. Prediction of bone mass density variation by bone remodeling markers in postmenopausal women with vitamin D insufficiency treated with calcium and vitamin D supplementation. Journal of Clinical Endocrinology & Metabolism. 2003;88:5175-9. [pmid: 14602746].
38 Grados F, Brazier M, Kamel S, Duver S, Heurtebize N, Maamer M, Mathieu M, Garabedian M, Sebert JL, Fardellone P. Effects on bone mineral density of calcium and vitamin D supplementation in elderly women with vitamin D deficiency. Joint, Bone, Spine: Revue du Rhumatisme. 2003;70:203-8.
39 Grant AM, Avenell A, Campbell MK, McDonald AM, MacLennan GS, McPherson GC, Anderson FH, Cooper C, Francis RM, Donaldson C, Gillespie WJ, Robinson CM, Torgerson DJ, Wallace WA. RECORD Trial Group. Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. 2005;365:1621-8. [pmid: 15885294].
40 Greer FR, Marshall S. Bone mineral content, serum vitamin D metabolite concentrations, and ultraviolet B light exposure in infants fed human milk with and without vitamin D2 supplements. Journal of Pediatrics. 1989;114:204-12. [pmid: 2783734].
41 Greer FR, Searcy JE, Levin RS, Steichen JJ, Steichen-Asche PS, Tsang RC. Bone mineral content and serum 25-hydroxyvitamin D concentrations in breast-fed infants with and without supplemental vitamin D: one-year follow-up. Journal of Pediatrics. 1982;100:919-22. [pmid: 6979622].
42 Greer FR, Searcy JE, Levin RS, Steichen JJ, Asch PS, Tsang RC. Bone mineral content and serum 25-hydroxyvitamin D concentration in breast-fed infants with and without supplemental vitamin D. Journal of Pediatrics. 1981;98:696-701. [pmid: 6971922].
43 Guillemant J, Le HT, Maria A, Allemandou A, Peres G, Guillemant S. Wintertime vitamin D deficiency in male adolescents: effect on parathyroid function and response to vitamin D3 supplements. Osteoporos Int. 2001;12:875-9. [pmid: 11716192].
44 Harris SS, Dawson-Hughes B. Plasma vitamin D and 25OHD responses of young and old men to supplementation with vitamin D3. Journal of the American College of Nutrition. 2002;21:357-62. [pmid: 12166534].
45 Harris SS, Dawson-Hughes B, Perrone GA. Plasma 25-hydroxyvitamin D responses of younger and older men to three weeks of supplementation with 1800 IU/day of vitamin D. Journal of the American College of Nutrition. 1999;18:470-4. [pmid: 10511329].
46 Harwood RH, Sahota O, Gaynor K, Masud T, Hosking DJ. A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age & Ageing. 2004;33:45-51. [pmid: 14695863].
47 Heaney RP, Davies KM, Chen TC, Holick MF, Barger-Lux MJ. Human serum 25-hydroxycholecalciferol response to extended oral dosing with cholecalciferol. American Journal of Clinical Nutrition. 2003;77:204-10. [pmid: 12499343].
48 Heaney RP, Barger-Lux MJ, Dowell MS, Chen TC, Holick MF. Calcium absorptive effects of vitamin D and its major metabolites. Journal of Clinical Endocrinology & Metabolism. 1997;82:4111-6. [pmid: 9398723].
49 Heikkinen A, Parviainen MT, Tuppurainen MT, Niskanen L, Komulainen MH, Saarikoski S. Effects of postmenopausal hormone replacement therapy with and without vitamin D3 on circulating levels of 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D. Calcified Tissue International. 1998;62:26-30. [pmid: 9405729].
50 Himmelstein S, Clemens TL, Rubin A, Lindsay R. Vitamin D supplementation in elderly nursing home residents increases 25(OH)D but not 1,25(OH)2D. American Journal of Clinical Nutrition. 1990;52:701-6. [pmid: 2403063].
51 Ho ML, Yen HC, Tsang RC, Specker BL, Chen XC, Nichols BL. Randomized study of sunshine exposure and serum 25-OHD in breast-fed infants in Beijing, China. Journal of Pediatrics. 1985;107:928-31. [pmid: 4067751].
52 Hollis BW, Wagner CL. Vitamin D requirements during lactation: high-dose maternal supplementation as therapy to prevent hypovitaminosis D for both the mother and the nursing infant. American Journal of Clinical Nutrition. 2004;80:1752S-8S. [pmid: 15585800].
53 Honkanen R, Alhava E, Parviainen M, Talasniemi S, Monkkonen R. The necessity and safety of calcium and vitamin D in the elderly. Journal of the American Geriatrics Society. 1990;38:862-6. [pmid: 2387950].
54 Hunter D, Major P, Arden N, Swaminathan R, Andrew T, MacGregor AJ, Keen R, Snieder H, Spector TD. A randomized controlled trial of vitamin D supplementation on preventing postmenopausal bone loss and modifying bone metabolism using identical twin pairs. Journal of Bone & Mineral Research. 2000;15:2276-83. [pmid: 11092410].
55 Jackson RD, LaCroix AZ, Gass M, Wallace RB, Robbins J, Lewis CE, Bassford T, Beresford SA, Black HR, Blanchette P, Bonds DE, Brunner RL, Brzyski RG, Caan B, Cauley JA, Chlebowski RT, Cummings SR, Granek I, Hays J, Heiss G, Hendrix SL, Howard BV, Hsia J, Hubbell FA, Johnson KC, Judd H, Kotchen JM, Kuller LH, Langer RD, Lasser NL, Limacher MC, Ludlam S, Manson JE, Margolis KL, Mcgowan J, Ockene JK, O'Sullivan MJ, Phillips L, Prentice RL, Sarto GE, Stefanick ML, Van HL, Wactawski-Wende J, Whitlock E, Anderson GL, Assaf AR, Barad D. Women's Health Initiative Investigators. Calcium plus vitamin D supplementation and the risk of fractures.[see comment]. New England Journal of Medicine. 2006;354:669-83. [pmid: 16481635].
56 Jensen C, Holloway L, Block G, Spiller G, Gildengorin G, Gunderson E, Butterfield G, Marcus R. Long-term effects of nutrient intervention on markers of bone remodeling and calciotropic hormones in late-postmenopausal women. American Journal of Clinical Nutrition. 2002;75:1114-20. [pmid: 12036821].
57 Johnson JL, Mistry VV, Vukovich MD, Hogie-Lorenzen T, Hollis BW, Specker BL. Bioavailability of vitamin D from fortified process cheese and effects on vitamin D status in the elderly. J Dairy Sci. 2005;88:2295-301. [pmid: 15956292].
58 Keane EM, Healy M, O'Moore R, Coakley D, Walsh JB. Vitamin D-fortified liquid milk: benefits for the elderly community-based population. Calcified Tissue International. 1998;62:300-2. [pmid: 9504953].
59 Kenny AM, Biskup B, Robbins B, Marcella G, Burleson JA. Effects of vitamin D supplementation on strength, physical function, and health perception in older, community-dwelling men. Journal of the American Geriatrics Society. 2003;51:1762-7. [pmid: 14687355].
60 Kenny AM, Prestwood KM, Biskup B, Robbins B, Zayas E, Kleppinger A, Burleson JA, Raisz LG. Comparison of the effects of calcium loading with calcium citrate or calcium carbonate on bone turnover in postmenopausal women. Osteoporos Int. 2004;15:290-4. [pmid: 14722627].
61 Khaw KT, Scragg R, Murphy S. Single-dose cholecalciferol suppresses the winter increase in parathyroid hormone concentrations in healthy older men and women: a randomized trial. American Journal of Clinical Nutrition. 1994;59:1040-4. [pmid: 8172088].
62 Komulainen MH, Kroger H, Tuppurainen MT, Heikkinen AM, Alhava E, Honkanen R, Saarikoski S. HRT and Vit D in prevention of non-vertebral fractures in postmenopausal women: a 5 year randomized trial. Maturitas. 1998;31:45-54. [pmid: 10091204].
63 Krieg MA, Jacquet AF, Bremgartner M, Cuttelod S, Thiebaud D, Burckhardt P. Effect of supplementation with vitamin D3 and calcium on quantitative ultrasound of bone in elderly institutionalized women: a longitudinal study. Osteoporos Int. 1999;9:483-8. [pmid: 10624454].
64 Larsen ER, Mosekilde L, Foldspang A. Vitamin D and calcium supplementation prevents osteoporotic fractures in elderly community dwelling residents: a pragmatic population-based 3-year intervention study. Journal of Bone & Mineral Research. 2004;19:370-8. [pmid: 15040824].
65 Larsen ER, Mosekilde L, Foldspang A. Vitamin D and calcium supplementation prevents severe falls in elderly community-dwelling women: a pragmatic population-based 3-year intervention study. Aging-Clinical & Experimental Research. 2005;17:125-32. [pmid: 15977461].
66 Latham NK, Anderson CS, Lee A, Bennett DA, Moseley A, Cameron ID. Fitness Collaborative Group. A randomized, controlled trial of quadriceps resistance exercise and vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). Journal of the American Geriatrics Society. 2003;51:291-9. [pmid: 12588571].
67 Lau EM, Woo J, Lam V, Hong A. Milk supplementation of the diet of postmenopausal Chinese women on a low calcium intake retards bone loss. Journal of Bone & Mineral Research. 2001;16:1704-9. [pmid: 11547841].
68 Law M, Withers H, Morris J, Anderson F. Vitamin D supplementation and the prevention of fractures and falls: results of a randomised trial in elderly people in residential accommodation. Age & Ageing. 2006;35:482-6. [pmid: 16641143].
69 Lips P, Graafmans WC, Ooms ME, Bezemer PD, Bouter LM. Vitamin D supplementation and fracture incidence in elderly persons: a randomized, placebo-controlled clinical trial. Annals of Internal Medicine. 1996;124:400-6. [pmid: 8554248].
70 Lips P, Wiersinga A, van Ginkel FC, Jongen MJ, Netelenbos JC, Hackeng WH, Delmas PD, van der Vijgh WJ. The effect of vitamin D supplementation on vitamin D status and parathyroid function in elderly subjects. Journal of Clinical Endocrinology & Metabolism. 1988;67:644-50. [pmid: 3417845].
71 Lovell GA, Byth JL, Craswell PW, Phillips PA, Thomas MJ. The influence of sunlight or dietary vitamin D on plasma 25-hydroxyvitamin D in institutionalized elderly patients in a sub-tropical climate. Journal of Human Nutrition & Dietetics. 1988;1:163-70.
72 Mastaglia SR, Mautalen CA, Parisi MS, Oliveri B. Vitamin D2 dose required to rapidly increase 25OHD levels in osteoporotic women. European Journal of Clinical Nutrition. 2006;60:681-7. [pmid: 16391587].
73 Mallet E, Gugi B, Brunelle P, Henocq A, Basuyau JP, Lemeur H. Vitamin D supplementation in pregnancy: a controlled trial of two methods. Obstetrics & Gynecology. 1986;68:300-4. [pmid: 3755517].
74 Marks R, Foley PA, Jolley D, Knight KR, Harrison J, Thompson SC. The Effect of Regular Sunscreen Use on Vitamin D Levels in an Australian Population. Archives of Dermatology. 1995;131:415-21. [pmid: 7726582].
75 Matsuoka LY, Wortsman J, Haddad JG, Hollis BW. Elevation of blood vitamin D2 levels does not impede the release of vitamin D3 from the skin. Metabolism: Clinical & Experimental. 1992;41:1257-60. [pmid: 1331703].
76 McKenna MJ, Freaney R, Byrne P, McBrinn Y, Murray B, Kelly M, Donne B, O'Brien M. Safety and efficacy of increasing wintertime vitamin D and calcium intake by milk fortification. QJM. 1995;88:895-8. [pmid: 8593549].
77 Meier C, Woitge HW, Witte K, Lemmer B, Seibel MJ. Supplementation with oral vitamin D3 and calcium during winter prevents seasonal bone loss: a randomized controlled open-label prospective trial. Journal of Bone & Mineral Research. 2004;19:1221-30. [pmid: 15231008].
78 Natri AM, Salo P, Vikstedt T, Palssa A, Huttunen M, Karkkainen MU, Salovaara H, Piironen V, Jakobsen J, Lamberg-Allardt CJ. Bread fortified with cholecalciferol increases the serum 25-hydroxyvitamin D concentration in women as effectively as a cholecalciferol supplement. Journal of Nutrition. 2006;136:123-7. [pmid: 16365070].
79 Nordin BE, Baker MR, Horsman A, Peacock M. A prospective trial of the effect of vitamin D supplementation on metacarpal bone loss in elderly women. American Journal of Clinical Nutrition. 1985;42:470-4. [pmid: 4036849].
80 Ooms ME, Roos JC, Bezemer PD, van der Vijgh WJ, Bouter LM, Lips P. Prevention of bone loss by vitamin D supplementation in elderly women: a randomized double-blind trial. Journal of Clinical Endocrinology & Metabolism. 1995;80:1052-8. [pmid: 7714065].
81 Orwoll ES, Weigel RM, Oviatt SK, McClung MR, Deftos LJ. Calcium and cholecalciferol: effects of small supplements in normal men. American Journal of Clinical Nutrition. 1988;48:127-30. [pmid: 2839025].
82 Palacios S, Castelo-Branco C, Cifuentes I, von Helde S, Baro L, Tapia-Ruano C, Menendez C, Rueda C. Changes in bone turnover markers after calcium-enriched milk supplementation in healthy postmenopausal women: a randomized, double-blind, prospective clinical trial. Menopause. 2005;12:63-8. [pmid: 15668602].
83 Panunzio MF, Pisano A, Telesforob P, Tomaiuolo P. Diet can increase 25-hydroxyvitamin-D3 plasma levels in the elderly: A dietary intervention trial. Nutr Res. 2003;23:1177-81.
84 Patel R, Collins D, Bullock S, Swaminathan R, Blake GM, Fogelman I. The effect of season and vitamin D supplementation on bone mineral density in healthy women: a double-masked crossover study. Osteoporos Int. 2001;12:319-25. [pmid: 11420782].
85 Pehlivan I, Hatun S, Aydogan M, Babaoglu K, Gokalp AS. Maternal vitamin D deficiency and vitamin D supplementation in healthy infants. Turkish Journal of Pediatrics. 2003;45:315-20. [pmid: 14768796].
86 Pfeifer M, Begerow B, Minne HW, Abrams C, Nachtigall D, Hansen C. Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women.[erratum appears in J Bone Miner Res 2001 Oct;16(10):1935]. Journal of Bone & Mineral Research. 2000;15:1113-8. [pmid: 10841179].
87 Porthouse J, Cockayne S, King C, Saxon L, Steele E, Aspray T, Baverstock M, Birks Y, Dumville J, Francis R, Iglesias C, Puffer S, Sutcliffe A, Watt I, Torgerson DJ. Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 2005;330:1003. [pmid: 15860827]. [pmcid: 557150].
88 Reid IR, Gallagher DJ, Bosworth J. Prophylaxis against vitamin D deficiency in the elderly by regular sunlight exposure. Age & Ageing. 1986;15:35-40. [pmid: 3953329].
89 Riis B, Christiansen C, Rodbro P. The effect of different vitamin D treatments on serum vitamin D levels in early postmenopausal women. Acta Vitaminologica et Enzymologica. 1984;6:77-82. [pmid: 6093487].
90 Rothberg AD, Pettifor JM, Cohen DF, Sonnendecker EW, Ross FP. Maternal-infant vitamin D relationships during breast-feeding. Journal of Pediatrics. 1982;101:500-3. [pmid: 7119949].
91 Schaafsma A, van Doormaal JJ, Muskiet FA, Hofstede GJ, Pakan I, van d V. Positive effects of a chicken eggshell powder-enriched vitamin-mineral supplement on femoral neck bone mineral density in healthy late post-menopausal Dutch women. British Journal of Nutrition. 2002;87:267-75. [pmid: 12064336].
92 Schaafsma A, Muskiet FA, Storm H, Hofstede GJ, Pakan I, van d V. Vitamin D(3) and vitamin K(1) supplementation of Dutch postmenopausal women with normal and low bone mineral densities: effects on serum 25-hydroxyvitamin D and carboxylated osteocalcin. European Journal of Clinical Nutrition. 2000;54:626-31. [pmid: 10951511].
93 Schou AJ, Heuck C, Wolthers OD. Vitamin D supplementation to healthy children does not affect serum osteocalcin or markers of type I collagen turnover. Acta Paediatrica. 2003;92:797-801. [pmid: 12892157].
94 Sebert JL, Garabedian M, Chauvenet M, Maamer M, Agbomson F, Brazier M. Evaluation of a new solid formulation of calcium and vitamin D in institutionalized elderly subjects : a randomized comparative trial versus separate administration of both constituents. Revue du Rhumatisme (English Edition). 1995;62:288-94.
95 Sorva A, Risteli J, Risteli L, Valimaki M, Tilvis R. Effects of vitamin D and calcium on markers of bone metabolism in geriatric patients with low serum 25-hydroxyvitamin D levels. Calcified Tissue International. 1991;49(Suppl):S88-S89. [pmid: 1933612].
96 Sorva A, Valimaki M, Tilvis R. Effects of vitamin D and calcium supplementation in geriatric patients with low vitamin D status. Arch Gerontol Geriatr. 1991;12:481-4.
97 Sorva A, Valimaki M, Risteli J, Risteli L, Elfving S, Takkunen H, Tilvis R. Serum ionized calcium, intact PTH and novel markers of bone turnover in bedridden elderly patients. European Journal of Clinical Investigation. 1994;24:806-12. [pmid: 7705374].
98 Specker BL, Ho ML, Oestreich A, Yin TA, Shui QM, Chen XC, Tsang RC. Prospective study of vitamin D supplementation and rickets in China. Journal of Pediatrics. 1992;120:733-9. [pmid: 1578308].
99 Stephens WP, Klimiuk PS, Berry JL, Mawer EB. Annual high-dose vitamin D prophylaxis in Asian immigrants. Lancet. 1981;2:1199-202. [pmid: 6118631].
100 Storm D, Eslin R, Porter ES, Musgrave K, Vereault D, Patton C, Kessenich C, Mohan S, Chen T, Holick MF, Rosen CJ. Calcium supplementation prevents seasonal bone loss and changes in biochemical markers of bone turnover in elderly New England women: a randomized placebo-controlled trial. Journal of Clinical Endocrinology & Metabolism. 1998;83:3817-25. [pmid: 9814452].
101 Tangpricha V, Koutkia P, Rieke SM, Chen TC, Perez AA, Holick MF. Fortification of orange juice with vitamin D: a novel approach for enhancing vitamin D nutritional health. American Journal of Clinical Nutrition. 2003;77:1478-83. [pmid: 12791627].
102 Tfelt-Hansen J, Torring O. Calcium and vitamin D3 supplements in calcium and vitamin D3 sufficient early postmenopausal healthy women. European Journal of Clinical Nutrition. 2004;58:1420-4. [pmid: 15114377].
103 Tjellesen L, Hummer L, Christiansen C, Rodbro P. Serum concentration of vitamin D metabolites during treatment with vitamin D2 and D3 in normal premenopausal women. Bone & Mineral. 1986;1:407-13. [pmid: 2849489].
104 Toss G, Andersson R, Diffey BL, Fall PA, Larko O, Larsson L. Oral vitamin D and ultraviolet radiation for the prevention of vitamin D deficiency in the elderly. Acta Paediatrica Scandinavica. 1982;212:157-61.
105 Trang HM, Cole DE, Rubin LA, Pierratos A, Siu S, Vieth R. Evidence that vitamin D3 increases serum 25-hydroxyvitamin D more efficiently than does vitamin D2. American Journal of Clinical Nutrition. 1998;68:854-8. [pmid: 9771862].
106 Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ. 2003;326:469. [pmid: 12609940]. [pmcid: 150177].
107 van der Klis FR, Jonxis JH, van Doormaal JJ, Sikkens P, Saleh AE, Muskiet FA. Changes in vitamin-D metabolites and parathyroid hormone in plasma following cholecalciferol administration to pre- and postmenopausal women in the Netherlands in early spring and to postmenopausal women in Curacao. British Journal of Nutrition. 1996;75:637-46. [pmid: 8672415].
108 Vieth R, Chan PC, MacFarlane GD. Efficacy and safety of vitamin D3 intake exceeding the lowest observed adverse effect level. American Journal of Clinical Nutrition. 2001;73:288-94. [pmid: 11157326].
109 Vieth R, Kimball S, Hu A, Walfish PG. Randomized comparison of the effects of the vitamin D3 adequate intake versus 100 mcg (4000 IU) per day on biochemical responses and the wellbeing of patients. Nutrition Journal. 2004;3:8. [pmid: 15260882]. [pmcid: 506781].
110 Weisman Y, Schen RJ, Eisenberg Z, Amarilio N, Graff E, Edelstein-Singer M, Goldray D, Harell A. Single oral high-dose vitamin D3 prophylaxis in the elderly. Journal of the American Geriatrics Society. 1986;34:515-8. [pmid: 3013967].
111 Zeghoud F, Ben Mekhbi H, Djeghri N, Garabedian M. Vitamin D prophylaxis during infancy: comparison of the long-term effects of three intermittent doses (15, 5, or 2.5 mg) on 25-hydroxyvitamin D concentrations. American Journal of Clinical Nutrition. 1994;60:393-6. [pmid: 8074071].
112 Zeghoud F, Vervel C, Guillozo H, Walrant-Debray O, Boutignon H, Garabedian M. Subclinical vitamin D deficiency in neonates: definition and response to vitamin D supplements. American Journal of Clinical Nutrition. 1997;65:771-8. [pmid: 9062528].