# Appendix D. Quality Assessment of RCTs

Study Identification | Study described as randomized | Methods used to describe the sequence of randomization | Study described as double blind | Method of double blinding described | Description of withdrawals | Total Jadad Score | Allocation Concealment
Ala-Houhala M. 1985^1^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Ala-Houhala M. 1988^2^ | 1 | 0 | 1 | 1 | 0 | 3 | U
Aloia JF. 2005^3^ | 1 | 1 | 1 | 1 | 1 | 5 | A
Anderson FH. 2004^4^ | 1 | 0 | 1 | 1 | 0 | 3 | U
Armas LA. 2004^5^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Baeksgaard L. 1998^6^ | 1 | 0 | 1 | 1 | 0 | 3 | U
Barnes MS. 2006^7^ | 1 | 0 | 1 | 0 | 1 | 3 | U
Bischoff HA. 2003^8^ | 1 | 0 | 1 | 1 | 0 | 3 | U
Brazier M. 2002^9^ | 1 | 1 | 1 | 1 | 0 | 4 | U
Brazier M. 2005^10^ | 1 | 1 | 1 | 1 | 0 | 4 | U
Brooke OG. 1980^11^ | 1 | 0 | 1 | 0 | 0 | 2 | U
Cesur Y. 2003^12^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Chan GM. 1995^13^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Chan GM. 1982^14^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Chapuy MC. 1992^15^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Chapuy MC. 2002^16^ | 1 | 0 | 1 | 1 | 0 | 3 | U
Chee WS. 2003^17^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Chel VG. 1998^18^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Cooper L. 2003^19^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Corless D. 1985^20^ | 1 | 1 | 1 | 1 | 1 | 5 | U
Daly RM. 2006^21^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Dawson-Hughes B. 1991^22^ | 1 | 0 | 1 | 0 | 1 | 3 | U
Dawson-Hughes B. 1997^23^
[Bischoff-Ferrari HA. 2006^24^ - companion paper] | 1 | 0 | 1 | 1 | 1 | 4 | U
Dawson-Hughes B. 1995^25^ | 1 | 0 | 1 | 0 | 1 | 2 | U
de Jong N. 1999^26^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Delvin E. 1986^27^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Deroisy R. 2002^28^ | 1 | 0 | 0 | 0 | 1 | 2 | I
Deroisy R. 1998^29^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Deroisy R. 1998^30^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Dhesi JK. 2004^31^ | 1 | 1 | 1 | 1 | 1 | 5 | U
Falkenbach A. 1993^32^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Flicker L. (2005)^33^ | 1 | 1 | 1 | 0 | 1 | 4 | U
Fuleihan G. (2006)^34^ | 1 | 1 | 1 | 1 | 0 | 4 | U
Goussous R. 2005^35^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Graafmans WC. 1996^36^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Grados F. 2003^37^
[Grados F. 2003 ^38^ - companion paper] | 1 | 0 | 1 | 1 | 1 | 4 | U
Grant A.M. 2005^39^ | 1 | 1 | 1 | 1 | 1 | 5 | A
Greer FR. 1989^40^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Greer FR. 1982^41^
[Greer FR. 1981^42^ - companion paper] | 1 | 0 | 1 | 1 | 0 | 3 | U
Guillemant J. 2001^43^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Harris SS. 2002^44^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Harris SS. 1999^45^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Harwood RH. 2004^46^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Heaney RP. 2003^47^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Heaney RP. 1997^48^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Heikkinen A. 1998^49^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Himmelstein S. 1990^50^ | 1 | 0 | 1 | 1 | 0 | 3 | U
Ho ML. 1985^51^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Hollis BW. 2004^52^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Honkanen R. 1990^53^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Hunter D. 2000^54^ | 1 | 1 | 1 | 1 | 1 | 5 | A
Jackson RD. 2006^55^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Jensen C. 2002^56^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Johnson JL. 2005^57^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Study A
Keane EM. 1998^58^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Kenny AM. 2003^59^ | 1 | 0 | 1 | 1 | 1 | 4 | A
Kenny AM. 2004^60^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Khaw KT. 1994^61^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Komulainen MH. 1998^62^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Krieg MA. 1999^63^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Larsen ER. 2005^64^
[Larsen ER. 2006^65^ - companion paper] | 1 | 0 | 0 | 0 | 0 | 1 | U
Latham NK. 2003^66^ | 1 | 1 | 1 | 1 | 1 | 5 | A
Lau EM. 2001^67^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Law M 2006^68^ | 1 | 1 | 0 | 0 | 0 | 2 | U
Lips P. 1996^69^ | 1 | 1 | 1 | 1 | 1 | 5 | A
Lips P. 1988^70^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Lovell GA. 1988^71^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Mastaglia SR. 2006^72^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Mallet E. 1986^73^ | 1 | 1 | 0 | 0 | 0 | 2 | U
Marks R. 1995^74^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Matsuoka LY. 1992^75^ | 1 | 0 | 0 | 0 | 0 | 1 | U
McKenna MJ. 1995^76^ | 1 | 0 | 1 | 0 | 0 | 2 | U
Meier C. 2004^77^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Natri AM. 2006^78^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Nordin BE. 1985^79^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Ooms ME. 1995^80^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Orwoll ES. 1988^81^ | 1 | 0 | 1 | 1 | 0 | 3 | U
Palacios S. 2005^82^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Panunzio MF. 2003^83^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Patel R. 2001^84^ | 1 | 0 | 1 | 1 | 0 | 3 | U
Pehlivan I. 2003^85^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Pfeifer M. 2000^86^ | 1 | 0 | 1 | 0 | 1 | 3 | U
Porthouse J. 2005^87^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Reid IR. 1986^88^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Riis B. 1984^89^ | 1 | 1 | 1 | 1 | 0 | 4 | U
Rothberg AD. 1982^90^ | 1 | 0 | 1 | 0 | 0 | 2 | U
Schaafsma A. 2002^91^
[Schaafsma A. 2000^92^ - companion paper] | 1 | 1 | 1 | 1 | 0 | 4 | U
Schou AJ. 2003^93^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Sebert JL. 1995^94^ | 1 | 1 | 0 | 0 | 1 | 3 | U
Sorva A. 1991^95^
[Sorva A. 1991^96^ & Sorva A. 1994^97^ - companion papers] | 1 | 0 | 0 | 0 | 0 | 1 | U
Specker BL. 1992^98^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Stephens WP. 1981^99^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Storm D. 1998^100^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Tangpricha V.2003^101^ | 1 | 1 | 1 | 1 | 0 | 4 | U
Tfelt-Hansen J. 2004^102^ | 1 | 0 | 1 | 1 | 1 | 4 | U
Tjellesen L. 1986^103^ | 1 | 0 | 1 | 1 | 0 | 3 | U
Toss G. 1982^104^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Trang HM. 1998^105^ | 1 | 0 | 1 | 0 | 0 | 2 | U
Trived DP. 2003^106^ | 1 | 0 | 1 | 1 | 0 | 3 | U
van der Klis FR. 1996^107^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Vieth R. 2001^108^ | 1 | 1 | 1 | 1 | 0 | 4 | U
Vieth R. 2004^109^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Weisman Y. 1986^110^ | 1 | 0 | 0 | 0 | 0 | 1 | U
Zeghoud F. 1994^111^ | 1 | 0 | 0 | 0 | 1 | 2 | U
Zeghoud F. 1997^112^ | 1 | 0 | 0 | 0 | 0 | 1 | U

Allocation Concealment: A = Adequate; I = Inadequate; U = Unclear