# Appendix C. Statistics Information Form

## Abbreviations

CV | coefficient of variation
SD | standard deviation
ANOVA | analysis of variance
ANCOVA | analysis of covariance
HR | hazard ratio
ITT | intention to treat
SE/SEM | standard error of the mean
HR | hazard ratio
RCT | randomized controlled trial
IQR | interquartile range
CI | confidence interval
S | significant
NS | not significant
OR | odds ratio
RR | relative risk

## Conversions

__ng/mL × 2.5 = _____ nmol/L 25(OH) D concentration

__ug X 40 = ____ IU D_2_/D_3_ supplementation