# Appendix B. Screening, Data Abstraction, and Quality Assessment Forms

## Article I. Screening Forms

### Level 1: Title and Abstract Screening

1 Is this an English-language publication?
  - Yes
  - No
  - Can't tell
2 Is this a potentially relevant record (exclude reviews) examining the safety and/or efficacy of Vit D (Vit D sources, dietary intake, sun exposure, supplements) in [underlined: humans] (exclude populations with secondary causes of osteoporosis)? ([underlined: examples]: bone health, fracture incidence, bone mineral density, rickets, fortified foods, supplementation, sun exposure, fall incidence (muscle strength/balance/body sway)
  OR addressing the association between circulating 25(OH)D and the above bone health outcomes.
  OR potential toxicity such as hypercalemia, or soft tissue calcification
  OR a record addressing issue of sunlight exposure and adequate vit D levels related to the risk of non-melanoma or melanoma skin cancer?
  - Yes
  - No
  - Can't tell
3 Please check all that apply (non-consequential):
  - Topic-relevant review article (important to screen reference list for possibly relevant citations)
  - NOT a topic-relevant review article
  - Letter to the editor, conference proceeding, editorial, abstract, magazine article etc.
  - Important for introduction/discussion sections
  - None of the above
  - Can't tell

### Level 2: Full Text Relevance Screening

1) Is this an English-language publication?
  a) Yes
  b) No
  c) Can't tell
2) Is this publication a Review article?
  a) Yes
  b) No
  c) Can't tell
3) . Does this report assess any of the following? (check all that apply)
  - (1) A primary study investigating the EFFECT of dietary sources of vit D (including fortified foods), sun exposure, and/or vit D supplementation (D2 or D3) on CIRCULATING 25 (OH) vit D concentrations
  - (2) A primary study investigating the ASSOCIATION between circulating 25 (OH) vit D concentrations on bone health outcomes (see Q#4 for outcomes of interest) in: 1. children 2. women of reproductive age 3. postmenopausal women and/or 4. elderly men
  - (3) A primary study investigating the EFFECT of supplemental vit D (D2 or D3) or vit D/calcium on BMD/BMC, fractures, and/or falls (muscle strength) of 1) women of reproductive age, 2) postmenopausal women, 3) elderly men
  - (4) A primary study reporting toxicity due to the EFFECT of supplementation of vit D (D2 or D3) such as hypercalcemia, soft tissue calcification, hypercalciuria, nephrocalcinosis, etc.
  - (5) A primary study examining the RELATIONSHIP between sun exposure, circulating 25 (OH) vit D concentrations on the risk of non-melanoma or melanoma skin cancer
  - None of the above
  - Can't tell
4) Does this study report ANY of the following health outcomes used to evaluate the association of 25 (OH) D? (This applies ONLY to Q3 answer #2)
1 BMD (bone mineral density)
2 BMC (bone mineral content)
3 Ultrasound
4 Falls (muscle strength/balance/sway)
5 Calcium absorption
6 Fracture incidence
7 PTH
8 Rickets

a Yes
b No
c Can't tell
d Not applicable
e Other

### Level 3: Study Design

1 Does this report belong to the following Levels of Evidence (see below)?
  a Yes
  b No
2 Level of Evidence of this report (check all that apply)
  a RCT parallel design
  b RCT crossover design
  c RCT factorial design
  d Controlled clinical trial (non-RCT)
  e Multiple prospective cohorts
  f At least one prospective cohort & one retrospective cohort
  g Case-control
  h Cross-sectional
  i Before-after (pre-post)
  j Single prospective cohort
  k Case series (non-comparative)
  l Case study
  m Sequential
  n Cross-national ecological analysis
  o Other: describe (text response)
  p Can't tell

### Level 4: Reference List Screening

1 Does this record contain references that may be relevant to this review?
  a Yes
  b No
2 Please indicate the reference # of citations to be retrieved: [text response].

## Article II. Data Extraction Verification Form

1 Initials of reviewer:
2 Reference identification # (Ref ID):
3 . Does this study have a companion paper? (e.g. subsequent/previous publications associated with the same data/patient set)
  a Yes (please list the companion Ref IDs)
  b No
4 Please indicate which of the following is the most appropriate description:
  a This was a primary extraction (please indicate if this was a companion in the text box)
  b This paper has been checked for consensus (please indicate if this was a companion using the text box)

## Article III. Quality Assessment Form — Randomized controlled Trials (Jadad Scale)

The Jadad instrument, as described in Jadad et al. 1996 (Controlled Clinical Trials 17:1) is as follows:

1. Was the study described as randomized (this includes the use of words such as randomly, random, and randomization)? yes = 1 point; no = 0 points

For question 1, give one additional point if the method to generate the sequence of randomization was described and it was appropriate (table of random numbers, computer generated, etc.).

For question 1, deduct 1 point if the method to generate the sequence of randomization as described and it was inappropriate (patients were allocated alternately, or according to date of birth, hospital number, etc.)

2. Was the study described as double blind? yes = 1 point; no = 0 points

For question 2, give 1 additional point if the method of doubling blinding was described and it was appropriate (identical placebo, active placebo, dummy, etc.).

For question 2, deduct 1 point if the method of double blinding was described and it was inappropriate (e.g., comparison of tablet vs injection with no double dummy).

3. Was there a description of withdrawals and dropouts? yes = 1 point; no = 0 points

Total possible score = 5 points

### Allocation Concealment

1 = yes; 0 = no

A: Adequate

- Sequentially numbered, opaque, sealed envelopes (SNOSE)
- Pharmacy controlled
- Numbered or ordered containers
- Central randomization - for example by telephone to a trials office or other method whose description contained elements convincing of concealment - for example a secure computer assisted method.

I: Inadequate

- Alternation
- Reference to case record numbers or to dates of birth

U: Unclear

- No mention of an allocation concealment approach at all
- An approach that. Does not fall into either adequate or inadequate allocation concealment