# Appendix J. List of Excluded Studies on the Basis Study Design (Level 3 screening)

Note: the following list of studies was excluded from the evidence synthesis on the basis of study design as determined by pre-set criteria for each key question.

## References

Abdul-Motaal A, Gettinby G, McIntosh WB, et al. Relationships between radiological and biochemical evidence of rickets in Asian schoolchildren. Postgrad Med J. 1985;61(714):307-312. [pmid: 4022859]. [pmcid: 2418223].
Abrams SA, Copeland KC, Gunn SK, et al. Calcium absorption and kinetics are similar in 7- and 8-year-old Mexican-American and Caucasian girls despite hormonal differences. Br J Nutr. 1999;129(3):666-671.
Abrams SA, Griffin IJ, Hawthorne KM, et al. Relationships among vitamin D levels, parathyroid hormone, and calcium absorption in young adolescents. J Clin Endocrinol Metab. 2005;90(10):5576-5581. [pmid: 16076940]. [pmcid: 1283091].
Abrams SA, Grusak MA, Stuff J, et al. Calcium and magnesium balance in 9–14-y-old children. Am J Clin Nutr. 1997;66(5):1172-1177. [pmid: 9356535].
Adams JS, Lee G. Gains in bone mineral density with resolution of vitamin D intoxication. Ann Intern Med. 1997;127(3):203-206. [pmid: 9245225].
Adams JS, Kantorovich V, Wu C, et al. Resolution of vitamin D insufficiency in osteopenic patients results in rapid recovery of bone mineral density. J Clin Endocrinol Metab. 1999;84(8):2729-2730. [pmid: 10443668].
Agarwal KS, Mughal MZ, Upadhyay P, et al. The impact of atmospheric pollution on vitamin D status of infants and toddlers in Delhi, India. Arch Dis Child. 2002;87(2):111-113. [pmid: 12138058]. [pmcid: 1719192].
Al Arabi KM, Elidrissy AW, Sedrani SH. Is avoidance of sunlight a cause of fractures of the femoral neck in elderly Saudis?. Tropical & Geographical Medicine. 1984;36(3):273-279. [pmid: 6506207].
Al Faraj S, Al Mutairi K. Vitamin D deficiency and chronic low back pain in Saudi Arabia. Spine. 2003;28(2):177-179. [pmid: 12544936].
Al Jurayyan NA, El Desouki ME, Al Herbish AS, et al. Nutritional rickets and osteomalacia in school children and adolescents. Saudi Med J. 2002;23(2):182-185. [pmid: 11938395].
Ala-Houhala M, Koskinen T, Parviainen MT, et al. 25-Hydroxyvitamin D and vitamin D in human milk: effects of supplementation and season. Am J Clin Nutr. 1988;48(4):1057-1060. [pmid: 3421201].
Alagol F, Shihadeh Y, Boztepe H, et al. Sunlight exposure and vitamin D deficiency in Turkish women. J Endocrinol Invest. 2000;23(3):173-177. [pmid: 10803475].
Albanese CV, Civitelli R, Tibollo FG, et al. Endocrine and physical determinants of bone mass in late postmenopause. Exp Clin Endocrinol Diabetes. 1996;104(3):263-270. [pmid: 8817245].
Aloia JF, Vaswani AN, Yeh JK, et al. Determinants of bone mass in postmenopausal women. Arch Intern Med. 1983;143(9):1700-1704. [pmid: 6615091].
Andersen R, Molgaard C, Skovgaard L T et al. Teenage girls and elderly women living in northern europe have low winter vitamin D status. Eur J Clin Nutr 2005;59(4):e-pub ahead of print
Anderson DM, Hollis BW, LeVine BR, et al. Dietary assessment of maternal vitamin D intake and correlation with maternal and neonatal serum vitamin D concentrations at delivery. Am J Perinatol. 1988;8(1):46-48.
Andiran N, Yordam N, Ozon A. Risk factors for vitamin D deficiency in breast-fed newborns and their mothers. Adv Nutr Res. 2002;18(1):47-50.
Ardawi MS, Nasra HAN, Ba'aqueel HSM, et al. Vitamin D status and calcium-regulating hormones in Saudi pregnant females and their babies: A cross-sectional study. Saudi Med J. 1997;18(1):15-24.
Arnaud SB, Matthusen M, Gilkinson JB, et al. Components of 25-hydroxyvitamin D in serum of young children in upper midwestern United States. Am J Clin Nutr. 1977;30(7):1082-1086. [pmid: 195455].
Arunabh S, Pollack S, Yeh J, et al. Body fat content and 25-hydroxyvitamin D levels in healthy women. J Clin Endocrinol Metab. 2003;88(1):157-161. [pmid: 12519845].
Arya V, Bhambri R, Godbole MM, et al. Vitamin D status and its relationship with bone mineral density in healthy Asian Indians. Osteoporos Int. 2004;15(1):56-61. [pmid: 13680103].
Atiq M, Suria A, Nizami SQ, et al. Vitamin D status of breastfed Pakistani infants. Acta Paediatr. 1998;87(7):737-740. [pmid: 9722245].
Atli T, Gullu S, Uysal AR, et al. The prevalence of Vitamin D deficiency and effects of ultraviolet light on Vitamin D levels in elderly Turkish population. Arch Gerontol Geriatr. 2005;40(1):53-60. [pmid: 15531023].
Awumey EM, Mitra DA, Hollis BW, et al. Vitamin D metabolism is altered in Asian Indians in the southern United States: a clinical research center study. J Clin Endocrinol Metab. 1998;83(1):169-173. [pmid: 9435436].
Bahijri SM. Serum 25-hydroxy cholecalciferol in infants and preschool children in the Western region of Saudi Arabia. Etiological factors. Saudi Med J. 2001;22(11):973-979. [pmid: 11744968].
Baker MR, McDonnell H, Peacock M, et al. Plasma 25-hydroxy vitamin D concentrations in patients with fractures of the femoral neck. Br Med J. 1979;1(6163):589. [pmid: 427455].
Barger-Lux MJ, Heaney RP. Effects of above average summer sun exposure on serum 25-hydroxyvitamin D and calcium absorption. J Clin Endocrinol Metab. 2002;87(11):4952-4956. [pmid: 12414856].
Barger-Lux MJ, Heaney RP, Dowell S, et al. Vitamin D and its major metabolites: serum levels after graded oral dosing in healthy men. Osteoporos Int. 1998;8(3):222-230. [pmid: 9797906].
Barth J, Gerlach B, Knuschke P, et al. Serum 25(OH)D3 and ultraviolet exposure of residents in an old people's home in Germany. Photodermatol Photoimmunol Photomed. 1992;9(5):229-231. [pmid: 1342194].
Bassir M, Laborie S, Lapillonne A, et al. Vitamin D deficiency in Iranian mothers and their neonates: a pilot study. Acta Paediatr. 2001;90(5):577-579. [pmid: 11430721].
Bates C J, Carter G D, Mishra G D et al. In a population study, can parathyroid hormone aid the definition of adequate vitamin D status? A study of people aged 65 years and over from the British National Diet and Nutrition Survey. Osteoporos Int 2003;14(2):
Bell NH. 25-Hydroxyvitamin D3 reverses alteration of the vitamin D-endocrine system in blacks.[erratum appears in Am J Med 1996 Aug;101(2):239]. Am J Med. 1995;99(6):597-599. [pmid: 7503080].
Benucci A, Tommasi M, Fantappie B, et al. Serum 25-hydroxyvitamin D levels in normal subjects: seasonal variations and relationships with parathyroid hormone and osteocalcin. J Nucl Biol Med. 1993;37(2):77-82. [pmid: 8373837].
Berlin T, Emtestam L, Bjorkhem I. Studies on the relationship between vitamin D3 status and urinary excretion of calcium in healthy subjects: effects of increased levels of 25-hydroxyvitamin D3. Scand J Clin Lab Invest. 1986;46(8):723-729. [pmid: 3026026].
Bettica P, Bevilacqua M, Vago T, et al. High prevalence of hypovitaminosis D among free-living postmenopausal women referred to an osteoporosis outpatient clinic in northern Italy for initial screening. Osteoporos Int. 1999;9(3):226-229. [pmid: 10450411].
Bhattoa HP, Bettembuk P, Ganacharya S, et al. Prevalence and seasonal variation of hypovitaminosis D and its relationship to bone metabolism in community dwelling postmenopausal Hungarian women. Osteoporos Int. 2004;15(6):447-451. [pmid: 15205715].
Bikle DD, Ettinger B, Sidney S, et al. Differences in calcium metabolism between black and white men and women. Miner Electrolyte Metab. 1999;25(3):178-184. [pmid: 10436403].
Bischoff HA, Stahelin HB, Tyndall A, et al. Relationship between muscle strength and vitamin D metabolites: are there therapeutic possibilities in the elderly?. Z Rheumatol. 2000;59(Suppl 1):39-41. [pmid: 10769434].
Bischoff HA, Stahelin HB, Urscheler N, et al. Muscle strength in the elderly: its relation to vitamin D metabolites. Arch Phys Med RehabilArch Phys Med Rehabil. 1999;80(1):54-58.
Bischoff H, Stahelin HB, Vogt P, et al. Immobility as a major cause of bone remodeling in residents of a long-stay geriatric ward. Calcif Tissue Int. 1999;64(6):485-489. [pmid: 10341020].
Bischoff-Ferrari HA, Dietrich T, Orav EJ, et al. Positive association between 25-hydroxy vitamin D levels and bone mineral density: a population-based study of younger and older adults. Am J Med. 2004;116(9):634-639. [pmid: 15093761].
Bischoff-Ferrari HA, Dietrich T, Orav EJ, et al. Higher 25-hydroxyvitamin D concentrations are associated with better lower-extremity function in both active and inactive persons aged greater than or equal to 60 y. Am J Clin Nutr. 2004;80(3):752-758. [pmid: 15321818].
Bischoff-Ferrari H A, Orav J E, Dawson-Hughes B. Effect of Vitamin D3 plus calcium on fall risk in older men and women: a 3-year randomized controlled trial. ASBMR 26th Annual Meeting 2004;Concurrent Oral : Osteoporosis: Treatment II : 10/5/2004 (Abstract #1221).
Blain H, Vuillemin A, Guillemin F, et al. Serum leptin level is a predictor of bone mineral density in postmenopausal women. J Clin Endocrinol Metab. 2002;87(3):1030-1035. [pmid: 11889157].
Blank S, Scanlon KS, Sinks TH, et al. An outbreak of hypervitaminosis D associated with the overfortification of milk from a home-delivery dairy. Am J Public Health. 1995;85(5):656-659. [pmid: 7733425]. [pmcid: 1615443].
Blok BH, Grant CC, McNeil AR, et al. Characteristics of children with florid vitamin D deficient rickets in the Auckland region in 1998. N Z Med J. 2000;113(1117):374-376. [pmid: 11050902].
Blumsohn A, Naylor KE, Timm W, et al. Absence of Marked Seasonal Change in Bone Turnover: A Longitudinal and Multicenter Cross-Sectional Study. J Bone Miner Res. 2003;18(7):1274-1281. [pmid: 12854838].
Bolland MJ, Grey AB, Ames RW, et al. Fat mass is an important predictor of parathyroid hormone levels in postmenopausal women. Bone. 2006;38(3):317-321. [pmid: 16199216].
Boonen S, Cheng XG, Nijs J, et al. Factors associated with cortical and trabecular bone loss as quantified by peripheral computed tomography (pQCT) at the ultradistal radius in aging women. Calcif Tissue Int. 1997;60(2):164-170. [pmid: 9056165].
Boonen S, Lesaffre E, Aerssens J, et al. Deficiency of the growth hormone-insulin-like growth factor-I axis potentially involved in age-related alterations in body composition.[see comment]. Gerontology. 1996;42(6):330-338. [pmid: 8930620].
Boonen S, Lesaffre E, Dequeker J, et al. Relationship between baseline insulin-like growth factor-I (IGF-I) and femoral bone density in women aged over 70 years: potential implications for the prevention of age-related bone loss. J Am Geriatr Soc. 1996;44(11):1301-1306. [pmid: 8909344].
Boonen S, Nicholson PH, Lowet G, et al. Determinants of age-associated changes in os calcis ultrasonic indices in elderly women: potential involvement of geriatric hyposomatotropism in bone fragility. Age & Ageing. 1997;26(2):139-146. [pmid: 9177671].
Booth SL, Tucker KL, McKeown NM, et al. Relationships between dietary intakes and fasting plasma concentrations of fat-soluble vitamins in humans. Br J Nutr. 1997;127(4):587-592.
Bouillon RA, Auwerx JH, Lissens WD, et al. Vitamin D status in the elderly: seasonal substrate deficiency causes 1,25-dihydroxycholecalciferol deficiency. Am J Clin Nutr. 1987;45(4):755-763. [pmid: 3494392].
Brazerol WF, McPhee AJ, Mimouni F, et al. Serial ultraviolet B exposure and serum 25 hydroxyvitamin D response in young adult American blacks and whites: no racial differences. J Am Coll Nutr. 1988;7(2):111-118. [pmid: 3361035].
Brazier M, Kamel S, Maamer M, et al. Markers of bone remodeling in the elderly subject: effects of vitamin D insufficiency and its correction. J Bone Miner Res. 1995;10(11):1753-1761. [pmid: 8592953].
Brock K, Wilkinson M, Cook R, et al. Associations with Vitamin D deficiency in “at risk” Australians. J Steroid Biochem Mol Biol. 2004;89–90(15):581-588.
Brooke OG, Brown IR, Cleeve HJ, et al. Observations on the vitamin D state of pregnant Asian women in London. Br J Obstet Gynaecol. 1981;88(1):18-26. [pmid: 7459287].
Brot C, Jorgensen N, Madsen OR, et al. Relationships between bone mineral density, serum vitamin D metabolites and calcium:phosphorus intake in healthy perimenopausal women. J Intern Med. 1999;245(5):509-516. [pmid: 10363752].
Brot C, Vestergaard P, Kolthoff N, et al. Vitamin D status and its adequacy in healthy Danish perimenopausal women: relationships to dietary intake, sun exposure and serum parathyroid hormone. Br J Nutr. 2001;86(Suppl):1S97-103.
Brown IR, Bakowska A, Millard PH. Vitamin D status of patients with femoral neck fractures. Age & Ageing. 1976;5(3):127-131. [pmid: 973586].
Bruce DG, St John A, Nicklason F, et al. Secondary hyperparathyroidism in patients from Western Australia with hip fracture: relationship to type of hip fracture, renal function, and vitamin D deficiency. J Am Geriatr Soc. 1999;47(3):354-359. [pmid: 10078900].
Brustad M, Alsaker E, Engelsen O, et al. Vitamin D status of middle-aged women at 65–71 degrees N in relation to dietary intake and exposure to ultraviolet radiation. Public Health Nutr. 2004;7(2):327-335. [pmid: 15003141].
Brustad M, Sandanger T, Aksnes L, et al. Vitamin D status in a rural population of northern Norway with high fish liver consumption. Public Health Nutr. 2004;7(6):783-789. [pmid: 15369617].
Brustad M, Sandanger T, Wilsgaard T, et al. Change in plasma levels of vitamin D after consumption of cod-liver and fresh cod-liver oil as part of the traditional north Norwegian fish dish “Molje”. Int J Circumpolar Health. 2003;62(1):40-53. [pmid: 12725340].
Budak N, Cicek B, Sahin H, et al. Bone mineral density and serum 25-hydroxyvitamin D level: Is there any difference according to the dressing style of the female university students. Int J Food Sci Nutr. 2004;55(7):569-575. [pmid: 16019301].
Burnand B, Sloutskis D, Gianoli F, et al. Serum 25-hydroxyvitamin D: distribution and determinants in the Swiss population. Am J Clin Nutr. 1992;56(3):537-542. [pmid: 1503066].
Cancela L, Le Boulch N, Miravet L. Relationship between the vitamin D content of maternal milk and the vitamin D status of nursing women and breast-fed infants. Rom J Endocrinol. 1986;110(1):43-50.
Cankurtaran M, Yavuz BB, Halil M, et al. General characteristics, clinical features and related factors of osteoporosis in a group of elderly Turkish men. Aging Clin Exp Res. 2005;17(2):108-115. [pmid: 15977458].
Canto-Costa MHS, Kunii I, Hauache OM. Body fat and cholecalciferol supplementaion in elderly homebound individuals. Braz J Med Biol Res. 2006;39(1):91-98. [pmid: 16400469].
Carnevale V, Modoni S, Pileri M, et al. Longitudinal evaluation of vitamin D status in healthy subjects from southern Italy: seasonal and gender differences. Osteoporos Int. 2001;12(12):1026-1030. [pmid: 11846328].
Center JR, Nguyen TV, Sambrook PN, et al. Hormonal and biochemical parameters and osteoporotic fractures in elderly men. J Bone Miner Res. 2000;15(7):1405-1411. [pmid: 10893691].
Center JR, Nguyen TV, Sambrook PN, et al. Hormonal and biochemical parameters in the determination of osteoporosis in elderly men. J Clin Endocrinol Metab. 1999;84(10):3626-3635. [pmid: 10523006].
Challa A, Ntourntoufi A, Cholevas V, et al. Breastfeeding and vitamin D status in Greece during the first 6 months of life. Eur J Pediatr. 2005;164(12):724-729. [pmid: 16143866].
Chapuy MC, Chapuy P, Meunier PJ. Calcium and vitamin D supplements: effects on calcium metabolism in elderly people. Am J Clin Nutr. 1987;46(2):324-328. [pmid: 3497572].
Chapuy MC, Chapuy P, Thomas JL, et al. Biochemical effects of calcium and vitamin D supplementation in elderly, institutionalized, vitamin D-deficient patients. Revue du Rhumatisme (English Edition). 1996;63(2):135-140.
Chapuy MC, Preziosi P, Maamer M, et al. Prevalence of vitamin D insufficiency in an adult normal population. Osteoporos Int. 1997;7(5):439-443. [pmid: 9425501].
Chapuy MC, Schott AM, Garnero P, et al. Healthy elderly French women living at home have secondary hyperparathyroidism and high bone turnover in winter. EPIDOS Study Group. J Clin Endocrinol Metab. 1996;81(3):1129-1133. [pmid: 8772587].
Charlton KE, Labadarios D, Lombard CJ, et al. Vitamin D status of older South Africans. S Afr Med J. 1996;86(11):1406-1410. [pmid: 8980560].
Cheng S, Tylavsky F, Kroger H, et al. Association of low 25-hydroxyvitamin D concentrations with elevated parathyroid hormone concentrations and low cortical bone density in early pubertal and prepubertal Finnish girls. Am J Clin Nutr. 2003;78(3):485-492. [pmid: 12936933].
Chesney RW, Rosen JF, Hamstra AJ, et al. Absence of seasonal variation in serum concentrations of 1,25-dihydroxyvitamin D despite a rise in 25-hydroxyvitamin D in summer. J Clin Endocrinol Metab. 1981;53(1):139-142. [pmid: 6972382].
Cheung EY, Ho AY, Lam KF, et al. Determinants of bone mineral density in Chinese men. Osteoporos Int. 2005;16(12):1481-1486. [pmid: 16133639].
Chuck A, Todd J, Diffey B. Subliminal ultraviolet-B irradiation for the prevention of vitamin D deficiency in the elderly: a feasibility study. Photodermatol Photoimmunol Photomed. 2001;17(4):168-171. [pmid: 11499538].
Cieslukowski Z, Lorenc RS, Lukaszkiewicz J. Insolation effect on vitamin D supply in children during sanatorium treatment. Acta Physiol Pol. 1984;35(4):373-381. [pmid: 6545931].
Cockburn F, Belton NR, Purvis RJ, et al. Maternal vitamin D intake and mineral metabolism in mothers and their newborn infants. Br Med J. 1980;281(6232):11-14. [pmid: 7407476]. [pmcid: 1713762].
Collins D, Jasani C, Fogelman I, et al. Vitamin D and bone mineral density. Osteoporos Int. 1998;8(2):110-114. [pmid: 9666932].
Congdon P, Horsman A, Kirby PA, et al. Mineral content of the forearms of babies born to Asian and white mothers. Br Med J (Clin Res Ed). 1983;286(6373):1233-1235.
Corless D, Gupta SP, Sattar DA, et al. Vitamin D status of residents of an old people's home and long-stay patients. Gerontology. 1979;25(6):350-355. [pmid: 510935].
Corless D, Gupta SP, Switala S, et al. Response of plasma-25-hydroxyvitamin D to ultraviolet irradiation in long-stay geriatric patients. Lancet. 1978;2(8091):649-651. [pmid: 80577].
Corstens F, Kerremans A, Claessens R. Resolution of massive technetium-99m methylene diphosphonate uptake in the stomach in vitamin D intoxication. Eur J Nucl Med. 1986;27(2):219-222.
Crocombe S, Mughal MZ, Berry JL. Symptomatic vitamin D deficiency among non-Caucasian adolescents living in the United Kingdom. Arch Dis Child. 2004;89(2):197-199. [pmid: 14736643].
Cumming RG, Cummings SR, Nevitt MC, et al. Calcium intake and fracture risk: results from the study of osteoporotic fractures. Am J Epidemiol. 1997;145(10):926-934. [pmid: 9149664].
Cummings SR. Endogenous Hormones and the Risk of Hip and Vertebral Fractures Among Older Women. N Engl J Med. 2006;339(11):733-738. [pmid: 9731089].
D'Amore M, Cantatore FP, Carrozzo M, et al. Serum 25(OH)D3 in the Apulian population (Southern Italy). Epidemiologic study. Panminerva Med. 1984;26(4):287-289. [pmid: 6533554].
Dabek JT. Plasma profile of hydroxylated vitamin D metabolites: methods and results in normals for spring-winter in Southern Finland. Ann Clin Res. 1980;12(1):17-24. [pmid: 7377752].
Dagnelie PC, Vergote FJ, van Staveren WA, et al. High prevalence of rickets in infants on macrobiotic diets. Am J Clin Nutr. 1990;51(2):202-208. [pmid: 2154918].
Dattani JT, Exton-Smith AN, Stephen JM. Vitamin D status of the elderly in relation to age and exposure to sunlight. Hum Nutr Clin Nutr. 1984;38(2):131-137. [pmid: 6706689].
Davie M, Lawson DE. Assessment of plasma 25-hydroxyvitamin D response to ultraviolet irradiation over a controlled area in young and elderly subjects. Clin Sci. 1980;58(3):235-242. [pmid: 7363564].
Davies DM. Calcium metabolism in healthy men deprived of sunlight. Ann N Y Acad Sci. 1985;453:21-27. [pmid: 3865582].
Davies M, Mawer EB, Hann JT, et al. Seasonal changes in the biochemical indices of vitamin D deficiency in the elderly: a comparison of people in residential homes, long-stay wards and attending a day hospital. Age & Ageing. 1986;15(2):77-83. [pmid: 3008525].
Davies PS, Bates CJ, Cole TJ, et al. Vitamin D: seasonal and regional differences in preschool children in Great Britain. Eur J Clin Nutr. 1999;53(3):195-198. [pmid: 10201800].
Dawodu A, Absood G, Patel M, et al. Biosocial factors affecting vitamin D status of women of childbearing age in the United Arab Emirates. J Biosoc Sci. 1998;30(4):431-437. [pmid: 9818552].
Dawodu A, Agarwal M, Hossain M, et al. Hypovitaminosis D and vitamin D deficiency in exclusively breast-feeding infants and their mothers in summer: a justification for vitamin D supplementation of breast-feeding infants. Eur J Pediatr. 2003;142(2):169-173.
Dawodu A, Dawson KP, Amirlak I, et al. Diet, clothing, sunshine exposure and micronutrient status of Arab infants and young children. Ann Trop Paediatr. 2001;21(1):39-44. [pmid: 11284245].
Dawson-Hughes B, Harris SS, Dallal GE. Plasma calcidiol, season, and serum parathyroid hormone concentrations in healthy elderly men and women. Am J Clin Nutr. 1997;65(1):67-71. [pmid: 8988915].
Dawson-Hughes B, Harris SS, Krall EA, et al. Effect of withdrawal of calcium and vitamin D supplements on bone mass in elderly men and women. Am J Clin Nutr. 2000;72(3):745-750. [pmid: 10966893].
DeLucia MC, Mitnick ME, Carpenter TO. Nutritional rickets with normal circulating 25-hydroxyvitamin D: a call for reexamining the role of dietary calcium intake in North American infants. J Clin Endocrinol Metab. 2003;88(8):3539-3545. [pmid: 12915633].
Delvin EE, Imbach A, Copti M. Vitamin D nutritional status and related biochemical indices in an autonomous elderly population. Am J Clin Nutr. 1988;48(2):373-378. [pmid: 3407617].
Delvin EE, Salle BL, Claris O, et al. Oral vitamin A, E and D supplementation of pre-term newborns either breast-fed or formula-fed: A 3-month longitudinal study. J Pediatr Gastroenterol Nutr. 2005;40(1):43-47. [pmid: 15625425].
Devgun MS, Johnson BE, Paterson CR. Ultraviolet radiation, weather and the blood levels of 25-hydroxyvitamin D. Clin Physiol Biochem. 1983;1(6):300-304. [pmid: 6680092].
Devine A, Wilson SG, Dick IM, et al. Effects of vitamin D metabolites on intestinal calcium absorption and bone turnover in elderly women. Am J Clin Nutr. 2002;75(2):283-288. [pmid: 11815319].
Dhesi JK, Bearne LM, Moniz C, et al. Neuromuscular and psychomotor function in elderly subjects who fall and the relationship with vitamin D status. J Bone Miner Res. 2002;17(5):891-897. [pmid: 12009020].
Dhesi JK, Moniz C, Close JC, et al. A rationale for vitamin D prescribing in a falls clinic population. Age & Ageing. 2002;31(4):267-271. [pmid: 12147564].
Di Monaco M, Vallero F, Di Monaco R, et al. 25-hydroxyvitamin D, parathyroid hormone, and functional recovery after hip fracture in elderly patients. J Bone Miner Metab. 2006;24(1):42-47. [pmid: 16369897].
Diamond TH, Ho KW, Rohl PG, et al. Annual intramuscular injection of a megadose of cholecalciferol for treatment of vitamin D deficiency: Efficacy and safety data. Med J Aust. 2005;183(1):1-4.
Diamond TH, Levy S, Smith A, et al. High bone turnover in Muslim women with vitamin D deficiency. Med J Aust. 2002;177(3):139-141. [pmid: 12149082].
Dibba B, Prentice A, Laskey MA, et al. An investigation of ethnic differences in bone mineral, hip axis length, calcium metabolism and bone turnover between West African and Caucasian adults living in the United Kingdom. Ann Hum Biol. 1999;26(3):229-242. [pmid: 10355494].
Dirschl DR, Henderson RC, Oakley WS. Correlates of bone mineral density in elderly patients with hip fractures. J Orthop Trauma. 1995;9(6):470-475. [pmid: 8592259].
Dlugos DJ, Perrotta PL, Horn WG. Effects of the submarine environment on renal-stone risk factors and vitamin D metabolism. Undersea Hyperb Med. 1995;22(2):145-152. [pmid: 7633276].
Docio S, Riancho JA, Perez A, et al. Seasonal deficiency of vitamin D in children: a potential target for osteoporosis-preventing strategies?. J Bone Miner Res. 1998;13(4):544-548. [pmid: 9556054].
Du X, Greenfield H, Fraser DR, et al. Vitamin D deficiency and associated factors in adolescent girls in Beijing. Am J Clin Nutr. 2001;74(4):494-500. [pmid: 11566648].
Du X, Zhu K, Trube A, et al. School-milk intervention trial enhances growth and bone mineral accretion in Chinese girls aged 10–12 years in Beijing. Br J Nutr. 2004;92(1):159-168. [pmid: 15230999].
Dubbelman R, Jonxis JH, Muskiet FA, et al. Age-dependent vitamin D status and vertebral condition of white women living in Curacao (The Netherlands Antilles) as compared with their counterparts in The Netherlands. Am J Clin Nutr. 1993;58(1):106-109. [pmid: 8317380].
Dukas L, Staehelin HB, Schacht E, et al. Better functional mobility in community-dwelling elderly is related to D-hormone serum levels and to daily calcium intake. J Nutr Health Aging. 2005;9(5):347-351. [pmid: 16222401].
Dunnigan MG, Fraser SA, McIntosh WB, et al. The prevention of vitamin D deficiency in the elderly. Scott Med J. 1986;31(3):144-149. [pmid: 3798077].
Duplessis C A, Harris E B, Watenpaugh D E et al. Vitamin D supplementation in underway submariners. Aviat Space Environ Med 2005;76(6):
Earnshaw SA, Worley A, Hosking DJ. Current diet does not relate to bone mineral density after the menopause. The Nottingham Early Postmenopausal Intervention Cohort (EPIC) Study Group. Br J Nutr. 1997;78(1):65-72. [pmid: 9292760].
Egsmose C, Lund B, McNair P, et al. Low serum levels of 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D in institutionalized old people: influence of solar exposure and vitamin D supplementation. Age & Ageing. 1987;16(1):35-40. [pmid: 3565167].
El Hajj FG, Nabulsi M, Choucair M, et al. Hypovitaminosis D in healthy schoolchildren. Pediatrics. 2001;107(4):E53. [pmid: 11335774].
el Sonbaty MR, Abdul-Ghaffar NU. Vitamin D deficiency in veiled Kuwaiti women. Eur J Clin Nutr. 1996;50(5):315-318. [pmid: 8735313].
Elidrissy AT, Sedrani SH, Lawson DE. Vitamin D deficiency in mothers of rachitic infants. Calcif Tissue Int. 1984;36(3):266-268. [pmid: 6432290].
Elliott ME, Binkley NC, Carnes M, et al. Fracture risks for women in long-term care: high prevalence of calcaneal osteoporosis and hypovitaminosis D. Pharmacotherapy. 2003;23(6):702-710. [pmid: 12820811].
Ellis G, Cooke WT. Serum concentrations of 25-hydroxy vitamin D in Europeans and Asians after oral vitamin D3. Br Med J. 1978;1(6114):685-686. [pmid: 204391]. [pmcid: 1603091].
Ellis G, Woodhead JS, Cooke WT. Serum-25-hydroxyvitamin-D concentrations in adolescent boys. Lancet. 1977;1(8016):825-828. [pmid: 67336].
Elmstahl S, Gullberg B, Janzon L, et al. Increased incidence of fractures in middle-aged and elderly men with low intakes of phosphorus and zinc. Osteoporos Int. 1998;8(4):333-340. [pmid: 10024903].
Fairney A, Fry J, Lipscomb A. The effect of darkness on vitamin D in adults. Postgrad Med J. 1979;55(642):248-250. [pmid: 471858]. [pmcid: 2428130].
Fairney A, Sloan MA, Patel KV, et al. Vitamin A and D status of black South African women and their babies. Hum Nutr Clin Nutr. 1987;41(1):81-87. [pmid: 3570865].
Falch JA, Steihaug S. Vitamin D deficiency in Pakistani premenopausal women living in Norway is not associated with evidence of reduced skeletal strength. Scand J Clin Lab Invest. 2000;60(2):103-109. [pmid: 10817396].
Falkenbach A, Sedlmeyer A. Travel to sunny countries is associated with changes in immunological parameters. Photodermatol Photoimmunol Photomed. 1997;13(4):139-142. [pmid: 9453082].
Falkenbach A, Sedlmeyer A, Unkelbach U. UVB radiation and its role in the treatment of postmenopausal women with osteoporosis. Int J Biometeorol. 1998;41(3):128-131. [pmid: 9531857].
Fardellone P, Sebert JL, Garabedian M, et al. Prevalence and biological consequences of vitamin D deficiency in elderly institutionalized subjects. Revue du Rhumatisme (English Edition). 1995;62(9):576-581.
Farrerons J, Barnadas M, Rodriguez J, et al. Clinically prescribed sunscreen (sun protection factor 15) does not decrease serum vitamin D concentration sufficiently either to induce changes in parathyroid function or in metabolic markers. Br J Dermatol. 1998;139(3):422-427. [pmid: 9767286].
Faulkner KA, Cauley JA, Zmuda JM, et al. Higher 1,25-dihydroxyvitamin D(3) concentrations associated with lower fall rates in older community-dwelling women. Osteoporos Int. 2006;17(9):1318-1328. [pmid: 16788853].
Finch PJ, Ang L, Colston KW, et al. Blunted seasonal variation in serum 25-hydroxy vitamin D and increased risk of osteomalacia in vegetarian London Asians. Eur J Clin Nutr. 1992;46(7):509-515. [pmid: 1623855].
Fonseca V, Agnew JE, Nag D, et al. Bone density and cortical thickness in nutritional vitamin D deficiency: effect of secondary hyperparathyroidism. Ann Clin Biochem. 1988;25(Pt 3):271-274. [pmid: 3400984].
Fonseca V, Tongia R, el Hazmi M, et al. Exposure to sunlight and vitamin D deficiency in Saudi Arabian women. Postgrad Med J. 1984;60(707):589-591. [pmid: 6483701]. [pmcid: 2418001].
Ford JA, McIntosh WV, Butterfield R, et al. Clinical and subclinical vitamin D deficiency in Bradford children. Arch Dis Child. 1976;51(12):939-943. [pmid: 1015846]. [pmcid: 1546158].
Fradinger EE, Zanchetta JR. Vitamin D and bone mineral density in ambulatory women living in Buenos Aires, Argentina. Osteoporos Int. 2001;12(1):24-27. [pmid: 11305079].
Francis RM, Peacock M, Taylor GA, et al. Calcium malabsorption in elderly women with vertebral fractures: evidence for resistance to the action of vitamin D metabolites on the bowel. Clin Sci. 1984;66(1):103-107. [pmid: 6606522].
Freaney R, McBrinn Y, McKenna MJ. Secondary hyperparathyroidism in elderly people: combined effect of renal insufficiency and vitamin D deficiency. Am J Clin Nutr. 1993;58(2):187-191. [pmid: 8338046].
Gallagher JC, Kinyamu HK, Fowler SE, et al. Calciotropic hormones and bone markers in the elderly. J Bone Miner Res. 1998;13(3):475-482. [pmid: 9525348].
Gannage-Yared MH, Azoury M, Mansour I, et al. Effects of a short-term calcium and vitamin D treatment on serum cytokines, bone markers, insulin and lipid concentrations in healthy post-menopausal women. J Endocrinol Invest. 2003;26(8):748-753. [pmid: 14669830].
Gannage-Yared MH, Chemali R, Yaacoub N, et al. Hypovitaminosis D in a sunny country: relation to lifestyle and bone markers. J Bone Miner Res. 2000;15(9):1856-1862. [pmid: 10977006].
Garnero P, Sornay-Rendu E, Chapuy MC, et al. Increased bone turnover in late postmenopausal women is a major determinant of osteoporosis. J Bone Miner Res. 1996;11(3):337-349. [pmid: 8852944].
Gessner BD, Plotnik J, Muth PT. 25-hydroxyvitamin D levels among healthy children in Alaska. Eur J Pediatr. 2003;143(4):434-437.
Ghannam NN, Hammami MM, Bakheet SM, et al. Bone mineral density of the spine and femur in healthy Saudi females: relation to vitamin D status, pregnancy, and lactation. Calcif Tissue Int. 1999;65(1):23-28. [pmid: 10369729].
Gibson RS, Bindra GS, Nizan P, et al. The vitamin D status of East Indian Punjabi immigrants to Canada. Br J Nutr. 1987;58(1):23-29. [pmid: 3040076].
Ginty F, Cavadini C, Michaud PA, et al. Effects of usual nutrient intake and vitamin D status on markers of bone turnover in Swiss adolescents. Eur J Clin Nutr. 2004;58(9):1257-1265. [pmid: 15054442].
Giovannucci E, Liu Y, Rimm EB, et al. Prospective study of predictors of vitamin D status and cancer incidence and mortality in men.[see comment]. J Natl Cancer Inst. 2006;98(7):451-459. [pmid: 16595781].
Glerup H, Mikkelsen K, Poulsen L, et al. Hypovitaminosis D myopathy without biochemical signs of osteomalacic bone involvement. Calcif Tissue Int. 2000;66(6):419-424. [pmid: 10821877].
Glerup H, Mikkelsen K, Poulsen L, et al. Commonly recommended daily intake of vitamin D is not sufficient if sunlight exposure is limited. J Intern Med. 2000;247(2):260-268. [pmid: 10692090].
Gloth FM, Gundberg CM, Hollis BW, et al. Vitamin D deficiency in homebound elderly persons. JAMA. 1995;274(21):1683-1686. [pmid: 7474272].
Gloth FM, Gundberg CM, Hollis BW, et al. Vitamin D deficiency in homebound elderly persons. JAMA. 1995;274(21):1683-1686. [pmid: 7474272].
Goel KM, Sweet EM, Logan RW, et al. Florid and subclinical rickets among immigrant children in Glasgow. Lancet. 1976;1(7970):1141-1145. [pmid: 58196].
Goldzieher JW, Zerwekh JE, Castracane VD. Single-monthly-dose vitamin D supplementation in elderly patients. Endocr Pract. 1999;5(5):229-232. [pmid: 15251658].
Gomez JM, Maravall FJ, Gomez N, et al. Relationship between 25-(OH) D3, the IGF-I system, leptin, anthropometric and body composition variables in a healthy, randomly selected population. Horm Metab Res. 2004;36(1):48-53. [pmid: 14983407].
Gomez-Alonso C, Naves-Diaz ML, Fernandez-Martin JL, et al. Vitamin D status and secondary hyperparathyroidism: the importance of 25-hydroxyvitamin D cut-off levels. Kidney Int Suppl. 2003;8563(S85):44-48.
Gordon CM, DePeter KC, Feldman HA, et al. Prevalence of vitamin D deficiency among healthy adolescents. Arch Pediatr Adolesc Med. 2004;158(6):531-537. [pmid: 15184215].
Goswami R, Gupta N, Goswami D, et al. Prevalence and significance of low 25-hydroxyvitamin D concentrations in healthy subjects in Delhi. Am J Clin Nutr. 2000;72(2):472-475. [pmid: 10919943].
Greenspan SL, Resnick NM, Parker RA. Vitamin D supplementation in older women. J Gerontol A Biol Sci Med Sci. 2005;60(6):754-759. [pmid: 15983179].
Gregg EW, Kriska AM, Salamone LM, et al. Correlates of quantitative ultrasound in the Women's Healthy Lifestyle Project. Osteoporos Int. 1999;10(5):416-424. [pmid: 10591840].
Griffiths AP, Fairney A. Effect of phototherapy on serum 25-hydroxyvitamin D in the Antarctic. Eur J Appl Physiol Occup Physiol. 1989;59(12):68-72. [pmid: 2583152].
Grover SR, Morley R. Vitamin D deficiency in veiled or dark-skinned pregnant women. Med J Aust. 2001;175(5):251-252. [pmid: 11587255].
Gruson M, Cancela L, Denne MA, et al. Relationship between bone GLA-protein (BGP) and calcidiol (25-hydroxycalciferol) in serum of breast-fed infants. Endocrinol Exp. 1986;20(23):329-334. [pmid: 3489605].
Guggenheim K, Kravitz M, Tal R, et al. Biochemical parameters of vitamin D nutriture in old people in Jerusalem. Ann Nutr Metab. 1979;23(3):172-178.
Guillemant J, Cabrol S, Allemandou A, et al. Vitamin D-dependent seasonal variation of PTH in growing male adolescents. Bone. 1995;17(6):513-516. [pmid: 8835303].
Guillemant S, Guillemant J, Feteanu D, et al. Effect of vitamin D3 administration on serum 25-hydroxyvitamin D3, 1,25-dihydroxyvitamin D3 and osteocalcin in vitamin D-deficient elderly people. J Steroid Biochem. 1989;33(6):1155-1159. [pmid: 2559250].
Gultekin A, Ozalp I, Hasanoglu A, et al. Serum-25-hydroxycholecalciferol levels in children and adolescents. Turk J Pediatr. 1987;29(3):155-162. [pmid: 3506361].
Guzel R, Kozanoglu E, Guler-Uysal F, et al. Vitamin D status and bone mineral density of veiled and unveiled Turkish women. J Womens Health Gend Based Med. 2001;10(8):765-770. [pmid: 11703889].
Haden ST, Fuleihan GE, Angell JE, et al. Calcidiol and PTH levels in women attending an osteoporosis program. Calcif Tissue Int. 1999;64(4):275-279. [pmid: 10089217].
Haney EM, Stadler D, Bliziotes MM. Vitamin D insufficiency in internal medicine residents. Calcif Tissue Int. 2005;76(1):11-16. [pmid: 15478001].
Harinarayan CV. Prevalence of vitamin D insufficiency in postmenopausal south Indian women. Osteoporos Int. 2005;16(4):397-402. [pmid: 15776219].
Harkness L, Cromer B. Low levels of 25-hydroxy vitamin D are associated with elevated parathyroid hormone in healthy adolescent females. Osteoporos Int. 2005;16(1):109-113. [pmid: 15175848].
Harkness LS, Cromer BA. Vitamin D deficiency in adolescent females. J Adolesc Health. 2005;37(1):75. [pmid: 15963911].
Harris SS, Dawson-Hughes B. Seasonal changes in plasma 25-hydroxyvitamin D concentrations of young American black and white women. Am J Clin Nutr. 1998;67(6):1232-1236. [pmid: 9625098].
Harris SS, Soteriades E, Coolidge JA, et al. Vitamin D insufficiency and hyperparathyroidism in a low income, multiracial, elderly population. J Clin Endocrinol Metab. 2000;85(11):4125-4130. [pmid: 11095443].
Hartwell D, Riis BJ, Christiansen C. Comparison of vitamin D metabolism in early healthy and late osteoporotic postmenopausal women. Calcif Tissue Int. 1990;47(6):332-337. [pmid: 2292078].
Hartwell D, Riis BJ, Christiansen C, et al. Bone metabolism and bone status in osteoporotic patients. Acta Med Scand. 1987;222(5):453-458. [pmid: 3425398].
Hartwell D, Rodbro P, Jensen SB, et al. Vitamin D metabolites—relation to age, menopause and endometriosis. Scand J Clin Lab Invest. 1990;50(2):115-121. [pmid: 2339276].
Hashemipour S, Larijani B, Adibi H, et al. Vitamin D deficiency and causative factors in the population of Tehran. BMC Public Health. 2004;4(1):38. [pmid: 15327695]. [pmcid: 517720].
Hatun S, Islam O, Cizmecioglu F, et al. Subclinical vitamin D deficiency is increased in adolescent girls who wear concealing clothing. Br J Nutr. 2005;135(2):218-222.
Hatun S, Ozkan B, Orbak Z, et al. Vitamin D deficiency in early infancy. Br J Nutr. 2005;135(2):279-282.
Heckmatt JZ, Peacock M, Davies AE, et al. Plasma 25-hydroxyvitamin D in pregnant Asian women and their babies. Lancet. 1979;2(8142):546-548. [pmid: 89556].
Heese H, Westcott D, Ryder C, et al. Prevalence of rickets at the age of 12 months. A study of appropriately developed for gestational age but premature infants. S Afr Med J. 1984;66(16):604-608. [pmid: 6541811].
Hegarty V, Woodhouse P, Khaw KT. Seasonal variation in 25-hydroxyvitamin D and parathyroid hormone concentrations in healthy elderly people. Age & Ageing. 1994;23(6):478-482. [pmid: 9231942].
Heikinheimo RJ, Haavisto MV, Harju EJ, et al. Serum vitamin D level after an annual intramuscular injection of ergocalciferol. Calcif Tissue Int. 1991;49(Suppl):S87. [pmid: 1933611].
Heikinheimo RJ, Inkovaara JA, Harju EJ, et al. Annual injection of vitamin D and fracture of aged bones. Calcif Tissue Int. 1992;51(2):105-110. [pmid: 1422948].
Heikinheimo R, Sievanen H, Jantti P, et al. Vitamin D treatment and bone mineral density in the aged. Maturitas. 1996;23(Suppl):S77-S80. [pmid: 8865145].
Henriksen C, Brunvand L, Stoltenberg C, et al. Diet and vitamin D status among pregnant Pakistani women in Oslo. Eur J Clin Nutr. 1995;49(3):211-218. [pmid: 7774537].
Hillman LS, Haddad JG. Perinatal vitamin D metabolism. III. Factors influencing late gestational human serum 25-hydroxyvitamin D. Am J Obstet Gynecol. 1976;125(2):196-200. [pmid: 1266899].
Hillman LS, Haddad JG. Perinatal vitamin D metabolism. II. Serial 25-hydroxyvitamin D concentrations in sera of term and premature infants. Eur J Pediatr. 1975;86(6):928-935.
Hillman LS, Chow W, Salmons SS, et al. Vitamin D metabolism, mineral homeostasis, and bone mineralization in term infants fed human milk, cow milk-based formula, or soy-based formula. Eur J Pediatr. 1988;112(6):864-874.
Hillman LS, Salmons S, Dokoh S. Serum 1,25-dihydroxyvitamin D concentrations in premature infants: preliminary results. Calcif Tissue Int. 1985;37(3):223-227. [pmid: 3926272].
Hine TJ, Roberts NB. Seasonal variation in serum 25-hydroxy vitamin D3 does not affect 1,25-dihydroxy vitamin D. Ann Clin Biochem. 1994;31(Pt 1):31-34. [pmid: 8154850].
Holdsworth MD, Dattani JT, Davies L, et al. Factors contributing to vitamin D status near retirement age. Hum Nutr Clin Nutr. 1984;38(2):139-149. [pmid: 6706690].
Holick MF, Siris ES, Binkley N, et al. Prevalence of Vitamin D inadequacy among postmenopausal North American women receiving osteoporosis therapy. J Clin Endocrinol Metab. 2005;90(6):3215-3224. [pmid: 15797954].
Holvik K, Meyer HE, Haug E, et al. Prevalence and predictors of vitamin D deficiency in five immigrant groups living in Oslo, Norway: The Oslo immigrant health study. Eur J Clin Nutr. 2005;59(1):57-63. [pmid: 15280907].
Hunt SP, O'Riordan JL, Windo J, et al. Vitamin D status in different subgroups of British Asians. Br Med J. 1976;2(6048):1351-1354. [pmid: 1000229]. [pmcid: 1690290].
Ilich JZ, Brownbill RA, Tamborini L. Bone and nutrition in elderly women: protein, energy, and calcium as main determinants of bone mineral density. Eur J Clin Nutr. 2003;57(4):554-565. [pmid: 12700617].
Inderjeeth CA, Barrett T, Al Lahham Y, et al. Seasonal variation, hip fracture and vitamin D levels in Southern Tasmania. N Z Med J. 2002;115(1152):183-185. [pmid: 12044001].
Inderjeeth CA, Nicklason F, Al Lahham Y, et al. Vitamin D deficiency and secondary hyperparathyroidism: clinical and biochemical associations in older non-institutionalised Southern Tasmanians. Aust N Z J Med. 2000;30(2):209-214. [pmid: 10833112].
Innes AM, Seshia MM, Prasad C, et al. Congenital rickets caused by maternal vitamin D deficiency. Paediatrics & Child Health. 2002;7(7):455-458. [pmid: 20046322].
Isaia G, Giorgino R, Rini GB, et al. Prevalence of hypovitaminosis D in elderly women in Italy: clinical consequences and risk factors. Osteoporos Int. 2003;14(7):577-582. [pmid: 12856111].
Ito M, Murakami T, Nagase T, et al. Vitamin D metabolism in a Japanese submarine crew after four-week deprivation of sunlight. Boei Ika Daigakko Zasshi. 2003;28(3):100-108.
Jacobus CH, Holick MF, Shao Q, et al. Hypervitaminosis D associated with drinking milk. N Engl J Med. 1992;326(18):1173-1177. [pmid: 1313547].
Jacques PF, Felson DT, Tucker KL, et al. Plasma 25-hydroxyvitamin D and its determinants in an elderly population sample. Am J Clin Nutr. 1997;66(4):929-936. [pmid: 9322570].
Jesudason D, Need AG, Horowitz M, et al. Relationship between serum 25-hydroxyvitamin D and bone resorption markers in vitamin D insufficiency. Bone. 2002;31(5):626-630. [pmid: 12477579].
Jones G, Blizzard C, Riley MD, et al. Vitamin D levels in prepubertal children in Southern Tasmania: prevalence and determinants. Eur J Clin Nutr. 1999;53(10):824-829. [pmid: 10556991].
Jones G, Dwyer T, Hynes KL, et al. Vitamin D insufficiency in adolescent males in Southern Tasmania: Prevalence, determinants, and relationship to bone turnover markers. Osteoporos Int. 2005;16(6):636-641. [pmid: 15448989].
Juttmann JR, Visser TJ, Buurman C, et al. Seasonal fluctuations in serum concentrations of vitamin D metabolites in normal subjects. Br Med J (Clin Res Ed). 1981;282(6273):1349-1352.
Kano K, Yoshida H, Yata J, et al. Age and seasonal variations in the serum levels of 25-hydroxyvitamin D and 24,25-dihydroxyvitamin D in normal humans. Endocrinol Jpn. 1980;27(2):215-221. [pmid: 6967810].
Katakity M, Webb JF, Dickerson JW. Some effects of a food supplement in elderly hospital patients: a longitudinal study. Hum Nutr Appl Nutr. 1983;37(2):85-93. [pmid: 6863026].
Kauppinen-Makelin R, Tahtela R, Loyttyniemi E, et al. A high prevalence of hypovitaminosis D in Finnish medical in- and outpatients. J Intern Med. 2001;249(6):559-563. [pmid: 11422663].
Keane EM, Healy M, O'Moore R, et al. Hypovitaminosis D in the healthy elderly. Br J Clin Pract. 1995;49(6):301-303. [pmid: 8554953].
Keane EM, Rochfort A, Cox J, et al. Vitamin-D-fortified liquid milk—a highly effective method of vitamin D administration for house-bound and institutionalised elderly. Gerontology. 1992;38(5):280-284. [pmid: 1427127].
Kenny AM, Gallagher JC, Prestwood KM, et al. Bone density, bone turnover, and hormone levels in men over age 75. J Gerontol A Biol Sci Med Sci. 1998;53(6):M419-M425. [pmid: 9823745].
Khaw KT, Sneyd MJ, Compston J. Bone density parathyroid hormone and 25-hydroxyvitamin D concentrations in middle aged women. BMJ. 1992;305(6848):273-277. [pmid: 1392857]. [pmcid: 1882724].
Kim JH, Moon SJ. Time spent outdoors and seasonal variation in serum concentrations of 25-hydroxyvitamin D in Korean women. Int J Food Sci Nutr. 2000;51(6):439-451. [pmid: 11271847].
Kinyamu HK, Gallagher JC, Balhorn KE, et al. Serum vitamin D metabolites and calcium absorption in normal young and elderly free-living women and in women living in nursing homes. Am J Clin Nutr. 1997;65(3):790-797. [pmid: 9062531].
Kinyamu HK, Gallagher JC, Rafferty KA, et al. Dietary calcium and vitamin D intake in elderly women: effect on serum parathyroid hormone and vitamin D metabolites. Am J Clin Nutr. 1998;67(2):342-348. [pmid: 9459385].
Kligman EW, Watkins A, Johnson K, et al. The impact of lifestyle factors on serum 25-hydroxy vitamin D levels in older adults: a preliminary study. Fam Pract Res J. 1989;9(1):11-19. [pmid: 2610008].
Kobayashi T, Okano T, Shida S, et al. Variation of 25-hydroxyvitamin D3 and 25-hydroxyvitamin D2 levels in human plasma obtained from 758 Japanese healthy subjects. J Nutr Sci Vitaminol (Tokyo). 1983;29(3):271-281. [pmid: 6604797].
Koenig J, Elmadfa I. Status of calcium and vitamin D of different population groups in Austria. Int J Vitam Nutr Res. 2000;70(5):214-220. [pmid: 11068701].
Kokkonen J, Koivisto M, Kirkinen P. Seasonal variation in serum-25-OH-D3 in mothers and newborn infants in northern finland. Acta Paediatr Scand. 1983;72(1):93-96. [pmid: 6858685].
Kokot F, Pietrek J, Cekanski A. Concentration of 25-hydroxyvitamin D (25-OH-D) in peripheral and uterine blood of pregnant women, in amniotic fluid and in the umbilical cord blood. Acta Med Pol. 1980;21(1):31-38. [pmid: 7405625].
Kokot F, Schmidt-Gayk H, Wiecek A et al. Influence of ultraviolet irradiation on plasma vitamin D and calcitonin levels in humans. Kidney Int Suppl 1989;27S143-S146.
Komar L, Nieves J, Cosman F, et al. Calcium homeostasis of an elderly population upon admission to a nursing home. J Am Geriatr Soc. 1993;41(10):1057-1064. [pmid: 8409150].
Krall EA, Sahyoun N, Tannenbaum S, et al. Effect of vitamin D intake on seasonal variations in parathyroid hormone secretion in postmenopausal women. N Engl J Med. 1989;321(26):1777-1783. [pmid: 2594036].
Kreiter SR, Schwartz RP, Kirkman HN, et al. Nutritional rickets in African American breast-fed infants. Eur J Pediatr. 2000;137(2):153-157.
Krieg MA, Cornuz J, Jacquet AF, et al. Influence of anthropometric parameters and biochemical markers of bone metabolism on quantitative ultrasound of bone in the institutionalized elderly. Osteoporos Int. 1998;8(2):115-120. [pmid: 9666933].
Kristinsson JO, Valdimarsson O, Sigurdsson G, et al. Serum 25-hydroxyvitamin D levels and bone mineral density in 16–20 years-old girls: lack of association. J Intern Med. 1998;243(5):381-388. [pmid: 9651561].
Kudlacek S, Schneider B, Peterlik M, et al. Assessment of vitamin D and calcium status in healthy adult Austrians.[comment]. Eur J Clin Invest. 2003;33(4):323-331. [pmid: 12662163].
Kuroda E, Okano T, Mizuno N, et al. Plasma levels of 25-hydroxyvitamin D2 and 25-hydroxyvitamin D3 in maternal, cord and neonatal blood. J Nutr Sci Vitaminol (Tokyo). 1981;27(1):55-65. [pmid: 6974772].
Kyriakidou-Himonas M, Aloia JF, Yeh JK. Vitamin D supplementation in postmenopausal black women. J Clin Endocrinol Metab. 1999;84(11):3988-3990. [pmid: 10566638].
Lamberg-Allardt C. Vitamin D intake, sunlight exposure and 25-hydroxyvitamin D levels in the elderly during one year. Ann Nutr Metab. 1984;28(3):144-150. [pmid: 6610382].
Lamberg-Allardt C. The relationship between serum 25-hydroxy-vitamin D levels and other variables related to calcium and phosphorus metabolism in the elderly. Acta Endocrinol (Copenh). 1984;105(1):139-144. [pmid: 6695540].
Lamberg-Allardt CJ, Outila TA, Karkkainen MU, et al. Vitamin D deficiency and bone health in healthy adults in Finland: could this be a concern in other parts of Europe?. J Bone Miner Res. 2001;16(11):2066-2073. [pmid: 11697803].
Lamberg-Allardt C, Ala-Houhala M, Ahola M, et al. Vitamin D status of children and adolescents in Finland. Ann Nutr Metab. 1986;30(4):267-272. [pmid: 3752926].
Lamberg-Allardt C, Karkkainen M, Seppanen R, et al. Low serum 25-hydroxyvitamin D concentrations and secondary hyperparathyroidism in middle-aged white strict vegetarians. Am J Clin Nutr. 1993;58(5):684-689. [pmid: 8237875].
Lamberg-Allardt C, Kirjarinta M, Dessypris AG. Serum 25-hydroxy-vitamin D, parathyroid hormone and calcium levels in adult inhabitants above the arctic circle in Northern Finland. Ann Clin Res. 1983;15(4):142-145. [pmid: 6651206].
Lamberg-Allardt C, Larjosto M, Schultz E. 25-Hydroxyvitamin D concentrations in maternal and cord blood at delivery and in maternal blood during lactation in Finland. Hum Nutr Clin Nutr. 1984;38(4):261-268. [pmid: 6088438].
Lamberg-Allardt C, von Knorring J, Slatis P, et al. Vitamin D status and concentrations of serum vitamin D metabolites and osteocalcin in elderly patients with femoral neck fracture: a follow-up study. Eur J Clin Nutr. 1989;43(5):355-361. [pmid: 2786805].
Landin-Wilhelmsen K, Wilhelmsen L, Wilske J, et al. Sunlight increases serum 25(OH) vitamin D concentration whereas 1,25(OH)2D3 is unaffected. Results from a general population study in Goteborg, Sweden (The WHO MONICA Project). Eur J Clin Nutr. 1995;49(6):400-407. [pmid: 7656883].
Lapatsanis D, Moulas A, Cholevas V, et al. Vitamin D: a necessity for children and adolescents in Greece. Calcif Tissue Int. 2005;77(6):348-355. [pmid: 16362463].
Lawson DE, Paul AA, Black AE, et al. Relative contributions of diet and sunlight to vitamin D state in the elderly. Br Med J. 1979;2(6185):303-305. [pmid: 476435]. [pmcid: 1595729].
Lawson M, Thomas M, Hardiman A. Dietary and lifestyle factors affecting plasma vitamin D levels in Asian children living in England. Eur J Clin Nutr. 1999;53(4):268-272. [pmid: 10334651].
Lee WT, Cheng JC, Jiang J, et al. Calcium absorption measured by stable calcium isotopes ((42)Ca & (44)Ca) among Northern Chinese adolescents with low vitamin D status. J Orthop Surg (Hong Kong). 2002;10(1):61-66. [pmid: 12401923].
Lee WT, Jiang J, Hu P, et al. Use of stable calcium isotopes (42Ca & 44Ca) in evaluation of calcium absorption in Beijing adolescents with low vitamin D status. Food Nutr Bull. 2002;23(3 Suppl):42-47. [pmid: 12362810].
Lehtonen-Veromaa M, Mottonen T, Irjala K, et al. Vitamin D intake is low and hypovitaminosis D common in healthy 9- to 15-year-old Finnish girls. Eur J Clin Nutr. 1999;53(9):746-751. [pmid: 10509773].
Lehtonen-Veromaa M, Mottonen T, Nuotio I, et al. The effect of conventional vitamin D(2) supplementation on serum 25(OH)D concentration is weak among peripubertal Finnish girls: a 3-y prospective study. Eur J Clin Nutr. 2002;56(5):431-437. [pmid: 12001014].
Lester E, Skinner RK, Foo AY, et al. Serum 25-hydroxyvitamin D levels and vitamin D intake in healthy young adults in Britain and Denmark. Scand J Clin Lab Invest. 1980;40(2):145-150. [pmid: 7256182].
Leung SS, Lui S, Swaminathan R. Vitamin D status of Hong Kong Chinese infants. Acta Paediatr Scand. 1989;78(2):303-306. [pmid: 2929354].
Levis S, Gomez A, Jimenez C, et al. Vitamin d deficiency and seasonal variation in an adult South Florida population. J Clin Endocrinol Metab. 2005;90(3):1557-1562. [pmid: 15634725].
Lichtenstein P, Specker BL, Tsang RC, et al. Calcium-regulating hormones and minerals from birth to 18 months of age: a cross-sectional study. I. Effects of sex, race, age, season, and diet on vitamin D status. Pediatrics. 1986;77(6):883-890. [pmid: 3487068].
Linhares ER, Jones DA, Round JM, et al. Effect of nutrition on vitamin D status: studies on healthy and poorly nourished Brazilian children. Am J Clin Nutr. 1984;39(4):625-630. [pmid: 6608872].
Lips P, Duong T, Oleksik A, et al. A global study of vitamin D status and parathyroid function in postmenopausal women with osteoporosis: baseline data from the multiple outcomes of raloxifene evaluation clinical trial. J Clin Endocrinol Metab. 2001;86(3):1212-1221. [pmid: 11238511].
Liu BA, Gordon M, Labranche JM, et al. Seasonal prevalence of vitamin D deficiency in institutionalized older adults. J Am Geriatr Soc. 1997;45(5):598-603. [pmid: 9158582].
Looker AC, Dawson-Hughes B, Calvo MS, et al. Serum 25-hydroxyvitamin D status of adolescents and adults in two seasonal subpopulations from NHANES III. Bone. 2002;30(5):771-777. [pmid: 11996918].
Lore F, Di Cairano G, Di Perri G. Vitamin D status in the extreme age of life. Ann Med Interne (Paris). 1986;137(3):209-211. [pmid: 3767186].
Lore F, Di Cairano G, Signorini AM, et al. Serum levels of 25-hydroxyvitamin D in postmenopausal osteoporosis. Calcif Tissue Int. 1981;33(5):467-470. [pmid: 6274485].
Lovell GA, Phillips PA, Thomas MJ. The effect of oral vitamin D supplementation on plasma 25 hydroxy vitamin D in institutionalized elderly patients in a subtropical climate: a twelve month follow-up. J Hum Nutr Diet. 1990;3(2):141-144.
Lowik MR, van den, Berg H, et al. Marginal nutritional status among institutionalized elderly women as compared to those living more independently (Dutch Nutrition Surveillance System). J Am Coll Nutr. 1992;11(6):673-681. [pmid: 1460181].
Lucas JA, Bolland MJ, Grey AB, et al. Determinants of vitamin D status in older women living in a subtropical climate. Osteoporos Int. 2005;16(12):1641-1648. [pmid: 16027959].
Lukert BP, Carey M, McCarty B, et al. Influence of nutritional factors on calcium-regulating hormones and bone loss. Calcif Tissue Int. 1987;40(3):119-125. [pmid: 3105841].
Lukert B, Higgins J, Stoskopf M. Menopausal bone loss is partially regulated by dietary intake of vitamin D. Calcif Tissue Int. 1992;51(3):173-179. [pmid: 1422960].
Lund B, Sorensen OH. Measurement of 25-hydroxyvitamin D in serum and its relation to sunshine, age and vitamin D intake in the Danish population. Scand J Clin Lab Invest. 1979;39(1):23-30. [pmid: 523951].
M'Buyamba-Kabangu JR, Fagard R, Lijnen P, et al. Calcium, vitamin D-endocrine system, and parathyroid hormone in black and white males. Calcif Tissue Int. 1987;41(2):70-74. [pmid: 3115547].
MacLennan WJ, Hamilton JC. Vitamin D supplements and 25-hydroxy vitamin D concentrations in the elderly. Br Med J. 1977;2(6091):859-861. [pmid: 922328]. [pmcid: 1631689].
MacLennan WJ, Hamilton JC, Darmady JM. The effects of season and stage of pregnancy on plasma 25-hydroxy-vitamin D concentrations in pregnant women. Postgrad Med J. 1980;56(652):75-79. [pmid: 7393799].
Maenpaa PH, Pirhonen A, Pirskanen A, et al. Biochemical indicators related to antioxidant status and bone metabolic activity in Finnish elderly men. Int J Vitam Nutr Res. 1989;59(1):14-19. [pmid: 2785977].
Maggio D, Cherubini A, Lauretani F, et al. 25(OH)D Serum levels decline with age earlier in women than in men and less efficiently prevent compensatory hyperparathyroidism in older adults. J Gerontol A Biol Sci Med Sci. 2005;60(11):1414-1419. [pmid: 16339327].
Malavolta N, Pratelli L, Frigato M, et al. The relationship of vitamin D status to bone mineral density in an Italian population of postmenopausal women. Osteoporos Int. 2005;16(12):1691-1697. [pmid: 15959621].
Markestad T. Effect of season and vitamin D supplementation on plasma concentrations of 25-hydroxyvitamin D in Norwegian infants. Acta Paediatr Scand. 1983;72(6):817-821. [pmid: 6673481].
Markestad T. Plasma concentrations of vitamin D metabolites in unsupplemented breast-fed infants. Eur J Pediatr. 1983;141(2):77-80. [pmid: 6662145].
Markestad T. Plasma concentrations of 1,25-dihydroxyvitamin D, 24,25-dihydroxyvitamin D, and 25,26-dihydroxyvitamin D in the first year of life. J Clin Endocrinol Metab. 1983;57(4):755-759. [pmid: 6604063].
Markestad T, Aksnes L, Ulstein M, et al. 25-Hydroxyvitamin D and 1,25-dihydroxyvitamin D of D2 and D3 origin in maternal and umbilical cord serum after vitamin D2 supplementation in human pregnancy. Am J Clin Nutr. 1984;40(5):1057-1063. [pmid: 6333810].
Markestad T, Elzouki A, Legnain M, et al. Serum concentrations of vitamin D metabolites in maternal and umbilical cord blood of Libyan and Norwegian women. Hum Nutr Clin Nutr. 1984;38(1):55-62. [pmid: 6607243].
Markestad T, Hesse V, Siebenhuner M, et al. Intermittent high-dose vitamin D prophylaxis during infancy: effect on vitamin D metabolites, calcium, and phosphorus. Am J Clin Nutr. 1987;46(4):652-658. [pmid: 3499065].
Markestad T, Kolmannskog S, Arntzen E, et al. Serum concentrations of vitamin D metabolites in exclusively breast-fed infants at 70 degrees north. Acta Paediatr Scand. 1984;73(1):29-32. [pmid: 6546635].
Markestad T, Ulstein M, Aksnes L, et al. Serum concentrations of vitamin D metabolites in vitamin D supplemented pregnant women. A longitudinal study. Acta Obstet Gynecol Scand. 1986;65(1):63-67. [pmid: 3487197].
Martinez ME, del Campo MT, Sanchez-Cabezudo MJ, et al. Relations between calcidiol serum levels and bone mineral density in postmenopausal women with low bone density. Calcif Tissue Int. 1994;55(4):253-256. [pmid: 7820775].
Matsuoka LY, Wortsman J, Hollis BW. Suntanning and cutaneous synthesis of vitamin D3. J Lab Clin Med. 1990;116(1):87-90. [pmid: 2165512].
Matsuoka LY, Wortsman J, Chen TC, et al. Compensation for the interracial variance in the cutaneous synthesis of vitamin D. J Lab Clin Med. 1995;126(5):452-457. [pmid: 7595030].
Matsuoka LY, Wortsman J, Haddad JG, et al. Racial pigmentation and the cutaneous synthesis of vitamin D. Arch Dermatol. 1991;127(4):536-538. [pmid: 1848745].
Matsuoka LY, Wortsman J, Hanifan N, et al. Chronic sunscreen use decreases circulating concentrations of 25-hydroxyvitamin D. A preliminary study. Arch Dermatol. 1988;124(12):1802-1804. [pmid: 3190255].
Matsuoka M, Otsuka H, Masuda S, et al. Changes in the concentrations of vitamin D and its metabolites in the plasma of healthy subjects orally given physiological doses of vitamin D2 by multivitamin or vitamin D preparations. J Nutr Sci Vitaminol (Tokyo). 1989;35(4):253-266. [pmid: 2585147].
Mawer EB, Berry JL, Sommer-Tsilenis E, et al. Ultraviolet irradiation increases serum 1,25-dihydroxyvitamin D in vitamin-D-replete adults. Miner Electrolyte Metab. 1984;10(2):117-121. [pmid: 6700563].
McAuley KA, Jones S, Lewis-Barned NJ, et al. Low vitamin D status is common among elderly Dunedin women. N Z Med J. 1997;110(1048):275-277. [pmid: 9269291].
McKenna MJ, Freaney R, Meade A, et al. Hypovitaminosis D and elevated serum alkaline phosphatase in elderly Irish people. Am J Clin Nutr. 1985;41(1):101-109. [pmid: 3966412].
McMurtry CT, Young SE, Downs RW, et al. Mild vitamin D deficiency and secondary hyperparathyroidism in nursing home patients receiving adequate dietary vitamin D. J Am Geriatr Soc. 1992;40(4):343-347. [pmid: 1556361].
McNeill G, Vyvyan J, Peace H, et al. Predictors of micronutrient status in men and women over 75 years old living in the community. Br J Nutr. 2002;88(5):555-561. [pmid: 12425736].
Meddeb N, Sahli H, Chahed M, et al. Vitamin D deficiency in Tunisia. Osteoporos Int. 2005;16(2):180-183. [pmid: 15197539].
Meier DE, Luckey MM, Wallenstein S, et al. Calcium, vitamin D, and parathyroid hormone status in young white and black women: association with racial differences in bone mass. J Clin Endocrinol Metab. 1991;72(3):703-710. [pmid: 1997523].
Melin AL, Wilske J, Ringertz H, et al. Vitamin D status, parathyroid function and femoral bone density in an elderly Swedish population living at home. Aging Clin Exp Res. 1999;11(3):200-207.
Meller Y, Kestenbaum RS, Galinsky D, et al. Seasonal variation in serum levels of vitamin D metabolites and parathormone in geriatric patients with fractures in Southern Israel. Isr J Med Sci. 1986;22(1):8-11. [pmid: 3485617].
Meulmeester JF, van den Berg H, et al. Vitamin D status, parathyroid hormone and sunlight in Turkish, Moroccan and Caucasian children in The Netherlands. Eur J Clin Nutr. 1990;44(6):461-470. [pmid: 2387281].
Meyer HE, Smedshaug GB, Kvaavik E, et al. Can vitamin D supplementation reduce the risk of fracture in the elderly? A randomized controlled trial. J Bone Miner Res. 2002;17(4):709-715. [pmid: 11918228].
Mezquita-Raya P, Munoz-Torres M, Luna JD, et al. Relation between vitamin D insufficiency, bone density, and bone metabolism in healthy postmenopausal women. J Bone Miner Res. 2001;16(8):1408-1415. [pmid: 11499863].
Mezquita-Raya P, Munoz-Torres M, Alonso G, et al. Susceptibility for postmenopausal osteoporosis: Interaction between genetic, hormonal and lifestyle factors. Calcif Tissue Int. 2004;75(5):373-379. [pmid: 15592793].
Mirsaeid Ghazi AA, Rais Zadeh F, Pezeshk P, et al. Seasonal variation of serum 25 hydroxy D3 in residents of Tehran. J Endocrinol Invest. 2004;27(7):676-679. [pmid: 15505993].
Mishal AA. Effects of different dress styles on vitamin D levels in healthy young Jordanian women. Osteoporos Int. 2001;12(11):931-935. [pmid: 11804019].
Miyako K, Kinjo S, Kohno H. Vitamin D deficiency rickets caused by improper lifestyle in Japanese children. Pediatr Int. 2005;47(2):142-146. [pmid: 15771690].
Moreiras O, Carbajal A, Perea I, et al. The influence of dietary intake and sunlight exposure on the vitamin D status in an elderly Spanish group. Int J Vitam Nutr Res. 1992;62(4):303-307. [pmid: 1291532].
Morris HA, Morrison GW, Burr M, et al. Vitamin D and femoral neck fractures in elderly South Australian women. Med J Aust. 1984;140(9):519-521. [pmid: 6708894].
Mowe M, Bohmer T, Haug E. Serum calcidiol and calcitriol concentrations in elderly people: Variations with age, sex, season and disease. Clin Nutr. 1996;15(4):201-206. [pmid: 16844035].
Mowe M, Haug E, Bohmer T. Low serum calcidiol concentration in older adults with reduced muscular function. J Am Geriatr Soc. 1999;47(2):220-226. [pmid: 9988294].
Mukamel MN, Weisman Y, Somech R, et al. Vitamin D deficiency and insufficiency in Orthodox and non-Orthodox Jewish mothers in Israel. Isr Med Assoc J. 2001;3(6):419-421. [pmid: 11433634].
Munger RG, Cerhan JR, Chiu BCH. Prospective study of dietary protein intake and risk of hip fracture in postmenopausal women. Am J Clin Nutr. 1999;69(1):147-152. [pmid: 9925137].
Murphy S, Khaw KT, Prentice A, et al. Relationships between parathyroid hormone, 25-hydroxyvitamin D, and bone mineral density in elderly men. Age & Ageing. 1993;22(3):198-204. [pmid: 8503316].
Najjar SS, Yazigi A. Abuse of vitamin D: a report on 15 cases of vitamin D poisoning. J Med Liban. 1972;25(1):113-122. [pmid: 4642997].
Nakamura K, Nashimoto M, Yamamoto M. Are the serum 25-hydroxyvitamin D concentrations in winter associated with forearm bone mineral density in healthy elderly Japanese women?. Int J Vitam Nutr Res. 2001;71(1):25-29. [pmid: 11276918].
Nakamura K, Nashimoto M, Yamamoto M. Summer/winter differences in the serum 25-hydroxyvitamin D3 and parathyroid hormone levels of Japanese women. Int J Biometeorol. 2000;44(4):186-189. [pmid: 11131290].
Nakamura K, Nashimoto M, Hori Y, et al. Serum parathyroid hormone in healthy Japanese women in relation to serum 25-hydroxyvitamin D. Int J Vitam Nutr Res. 2000;70(6):287-292. [pmid: 11214353].
Nakamura K, Nashimoto M, Hori Y, et al. Serum 25-hydroxyvitamin D concentrations and related dietary factors in peri- and postmenopausal Japanese women. Am J Clin Nutr. 2000;71(5):1161-1165. [pmid: 10799378].
Nakamura K, Nashimoto M, Hori Y, et al. Serum 25-hydroxyvitamin D levels in active women of middle and advanced age in a rural community in Japan. Adv Nutr Res. 1999;15(1112):870-873.
Nakamura K, Nashimoto M, Matsuyama S, et al. Low serum concentrations of 25-hydroxyvitamin D in young adult Japanese women: a cross sectional study. Adv Nutr Res. 2001;17(1112):921-925.
Nakamura K, Nashimoto M, Tsuchiya Y, et al. Vitamin D insufficiency in Japanese female college students: a preliminary report. Int J Vitam Nutr Res. 2001;71(5):302-305. [pmid: 11725695].
Nakamura K, Nishiwaki T, Ueno K, et al. Serum 25-hydroxyvitamin D levels and activities of daily living in noninstitutionalized elderly Japanese requiring care. J Bone Miner Metab. 2005;23(6):488-494. [pmid: 16261457].
Nakamura K, Ueno K, Nishiwaki T, et al. Nutrition, mild hyperparathyroidism, and bone mineral density in young Japanese women. Am J Clin Nutr. 2005;82(5):1127-1133. [pmid: 16280448].
Nako Y, Tomomasa T, Morikawa A. Risk of hypervitaminosis D from prolonged feeding of high vitamin D premature infant formula. Pediatr Int. 2004;46(4):439-443. [pmid: 15310310].
Narchi H, El Jamil M, Kulaylat N. Symptomatic rickets in adolescence. Arch Dis Child. 2001;84(6):501-503. [pmid: 11369569]. [pmcid: 1718804].
Nashimoto M, Nakamura K, Matsuyama S, et al. Hypovitaminosis D and hyperparathyroidism in physically inactive elderly Japanese living in nursing homes: relationship with age, sunlight exposure and activities of daily living. Aging Clin Exp Res. 2002;14(1):5-12.
Nayal AS, MacLennan WJ, Hamilton JC, et al. 25-hydroxy-vitamin D, diet and sunlight exposure in patients admitted to a geriatric unit. Gerontology. 1978;24(2):117-122. [pmid: 618770].
Need AG, Horowitz M, Morris HA, et al. Vitamin D status: effects on parathyroid hormone and 1, 25-dihydroxyvitamin D in postmenopausal women. Am J Clin Nutr. 2000;71(6):1577-1581. [pmid: 10837301].
Need AG, Morris HA, Horowitz M, et al. Effects of skin thickness, age, body fat, and sunlight on serum 25-hydroxyvitamin D. Am J Clin Nutr. 1993;58(6):882-885. [pmid: 8249872].
Need AG, O'Loughlin PD, Morris HA, et al. The effects of age and other variables on serum parathyroid hormone in postmenopausal women attending an osteoporosis center. J Clin Endocrinol Metab. 2004;89(4):1646-1649. [pmid: 15070925].
Nehama H, Wientroub S, Eisenberg Z, et al. Seasonal variation in paired maternal-newborn serum 25-hydroxyvitamin D and 24,25-dihydroxyvitamin D concentrations in Israel. Isr J Med Sci. 1987;23(4):274-277. [pmid: 3497905].
Nesby-O'Dell S, Scanlon KS, Cogswell ME, et al. Hypovitaminosis D prevalence and determinants among African American and white women of reproductive age: third National Health and Nutrition Examination Survey, 1988-1994. Am J Clin Nutr. 2002;76(1):187-192. [pmid: 12081833].
Newton HM, Sheltawy M, Hay AW, et al. The relations between vitamin D2 and D3 in the diet and plasma 25OHD2 and 25OHD3 in elderly women in Great Britain. Am J Clin Nutr. 1985;41(4):760-764. [pmid: 2984915].
Nordin BE, Need AG, Morris HA, et al. Effect of age on calcium absorption in postmenopausal women. Am J Clin Nutr. 2004;80(4):998-1002. [pmid: 15447911].
Nozza JM, Rodda CP. Vitamin D deficiency in mothers of infants with rickets. Med J Aust. 2001;175(5):253-255. [pmid: 11587256].
Nyomba BL, Auwerx J, Bormans V, et al. Pancreatic secretion in man with subclinical vitamin D deficiency. Diabetologia. 1986;29(1):34-38. [pmid: 3754230].
O'Dowd KJ, Clemens TL, Kelsey JL, et al. Exogenous calciferol (vitamin D) and vitamin D endocrine status among elderly nursing home residents in the New York City area. J Am Geriatr Soc. 1993;41(4):414-421. [pmid: 8463529].
O'Hare AE, Uttley WS, Belton NR, et al. Persisting vitamin D deficiency in the Asian adolescent. Arch Dis Child. 1984;59(8):766-770. [pmid: 6476877]. [pmcid: 1628627].
Obinata I, Tamiya Y, Hatakeyama K, et al. Changes in biochemical markers of bone turnover and in calcaneal ultrasonometric parameters during wintering in the Antarctic. Acta Med Biolog. 2002;50(3):125-134.
Okonofua F, Houlder S, Bell J, et al. Vitamin D nutrition in pregnant Nigerian women at term and their newborn infants. J Clin Pathol. 1986;39(6):650-653. [pmid: 3722419]. [pmcid: 499982].
Oliveri B, Cassinelli H, Mautalen C, et al. Vitamin D prophylaxis in children with a single dose of 150000 IU of vitamin D. Eur J Clin Nutr. 1996;50(12):807-810. [pmid: 8968701].
Oliveri B, Plantalech L, Bagur A, et al. High prevalence of vitamin D insufficiency in healthy elderly people living at home in Argentina. Eur J Clin Nutr. 2004;58(2):337-342. [pmid: 14749755].
Oliveri B, Zeni S, Lorenzetti MP, et al. Effect of one year residence in Antarctica on bone mineral metabolism and body composition. Eur J Clin Nutr. 1999;53(2):88-91. [pmid: 10099939].
Oliveri MB, Ladizesky M, Mautalen CA, et al. Seasonal variations of 25 hydroxyvitamin D and parathyroid hormone in Ushuaia (Argentina), the southernmost city of the world. Bone Miner. 1993;20(1):99-108. [pmid: 8453326].
Oliveri MB, Mautalen C, Bustamante L, et al. Serum levels of 25-hydroxyvitamin D in a year of residence on the Antarctic continent. Eur J Clin Nutr. 1994;48(6):397-401. [pmid: 7925221].
Omdahl JL, Garry PJ, Hunsaker LA, et al. Nutritional status in a healthy elderly population: vitamin D. Am J Clin Nutr. 1982;36(6):1225-1233. [pmid: 7148741].
Ong SP, Ryley J, Bashir T, et al. Nutrient intake and associated biochemical status of pregnant Asians in the United Kingdom. Hum Nutr Appl Nutr. 1983;37(1):23-29. [pmid: 6841129].
Ono Y, Suzuki A, Kotake M, et al. Seasonal changes of serum 25-hydroxyvitamin D and intact parathyroid hormone levels in a normal Japanese population. J Bone Miner Metab. 2005;23(2):147-151. [pmid: 15750693].
Ooms ME, Lips P, Roos JC, et al. Vitamin D status and sex hormone binding globulin: determinants of bone turnover and bone mineral density in elderly women. J Bone Miner Res. 1995;10(8):1177-1184. [pmid: 8585420].
Osler M, Schroll M. A dietary study of the elderly in the City of Roskilde 1988/1989 (II). A nutritional risk assessment. Dan Med Bull. 1991;38(5):410-413. [pmid: 1802628].
Otto-Buczkowska E, Kokot F, Wiedermann G, et al. Blood 25-OH-D levels in children. Critical remarks on current prophylaxis of rachitis. Acta Univ Carol [Med] (Praha). 1986;32(56):327-331.
Outila TA, Karkkainen MU, Lamberg-Allardt CJ. Vitamin D status affects serum parathyroid hormone concentrations during winter in female adolescents: associations with forearm bone mineral density. Am J Clin Nutr. 2001;74(2):206-210. [pmid: 11470722].
Outila TA, Karkkainen MU, Seppanen RH, et al. Dietary intake of vitamin D in premenopausal, healthy vegans was insufficient to maintain concentrations of serum 25-hydroxyvitamin D and intact parathyroid hormone within normal ranges during the winter in Finland. J Am Diet Assoc. 2000;100(4):434-441. [pmid: 10767899].
Overgaard K, Nilas L, Johansen JS, et al. Lack of seasonal variation in bone mass and biochemical estimates of bone turnover. Bone. 1988;9(5):285-288. [pmid: 3203016].
Pal BR, Marshall T, James C, et al. Distribution analysis of vitamin D highlights differences in population subgroups: preliminary observations from a pilot study in UK adults. Rom J Endocrinol. 2003;179(1):119-129.
Papapoulos SE, Clemens TL, Fraher LJ, et al. Metabolites of vitamin D in human vitamin-D deficiency: effect of vitamin D3 or 1,25-dihydroxycholecalciferol. Lancet. 1980;2(8195 pt 1):612-615. [pmid: 6107407].
Park W, Paust H, Kaufmann HJ, et al. Osteomalacia of the mother—rickets of the newborn. Eur J Pediatr. 1987;146(3):292-293. [pmid: 3036531].
Parviainen MT, Koskinen T. Vitamin A, D and E status in a Finnish population—a multivitamin study. Hum Nutr Clin Nutr. 1983;37(6):397-403. [pmid: 6689418].
Parviainen MT, Kumpusalo E, Halonen P, et al. Epidemiology of vitamins A, E, D and C in rural villages in Finland: biochemical, nutritional and socioeconomical aspects. Int J Vitam Nutr Res. 1992;62(3):238-243. [pmid: 1473905].
Pasco JA, Henry MJ, Kotowicz MA, et al. Seasonal periodicity of serum vitamin D and parathyroid hormone, bone resorption, and fractures: the Geelong Osteoporosis Study. J Bone Miner Res. 2004;19(5):752-758. [pmid: 15068498].
Pasco JA, Henry MJ, Nicholson GC, et al. Vitamin D status of women in the Geelong Osteoporosis Study: association with diet and casual exposure to sunlight. Med J Aust. 2001;175(8):401-405. [pmid: 11700831].
Paterson CR. Vitamin-D poisoning: survey of causes in 21 patients with hypercalcaemia. Lancet. 1980;1(8179):1164-1165. [pmid: 6103986].
Paunier L, Lacourt G, Pilloud P, et al. 25-hydroxyvitamin D and calcium levels in maternal, cord and infant serum in relation to maternal vitamin D intake. Helv Paediatr Acta. 1978;33(2):95-103. [pmid: 659262].
Peacey SR, Wright D, Harries MJ. Failure to normalize parathyroid hormone during treatment of vitamin D deficiency in Asian patients. Clin Endocrinol (Oxf). 2004;61(5):603-606. [pmid: 15521963].
Pehlivan I, Hatun S, Aydogan M, et al. Maternal serum vitamin D levels in the third trimester of pregnancy. Turkish Journal of Medical Sciences. 2002;32(3):237-241.
Pepe J, Romagnoli E, Nofroni I, et al. Vitamin D status as the major factor determining the circulating levels of parathyroid hormone: A study in normal subjects. Osteoporos Int. 2005;16(7):805-812. [pmid: 15551058].
Perry HM, Bernard M, Horowitz M, et al. The effect of aging on bone mineral metabolism and bone mass in Native American women. J Am Geriatr Soc. 1998;46(11):1418-1422. [pmid: 9809765].
Perry HM, Horowitz M, Morley JE, et al. Aging and bone metabolism in African American and Caucasian women. J Clin Endocrinol Metab. 1996;81(3):1108-1117. [pmid: 8772584].
Perry HM, Horowitz M, Morley JE, et al. Longitudinal changes in serum 25-hydroxyvitamin D in older people. Metab Clin Exp. 1999;48(8):1028-1032. [pmid: 10459569].
Pettifor JM, Isdale JM, Sahakian J, et al. Diagnosis of subclinical rickets. Arch Dis Child. 1980;55(2):155-157. [pmid: 7377839]. [pmcid: 1626677].
Pettifor JM, Ross FP, Solomon L. Seasonal variation in serum 25-hydroxycholecalciferol concentrations in elderly South African patients with fractures of femoral neck. Br Med J. 1978;1(6116):826-827. [pmid: 638475]. [pmcid: 1603526].
Pfeifer M, Begerow B, Minne HW, et al. Vitamin D status, trunk muscle strength, body sway, falls, and fractures among 237 postmenopausal women with osteoporosis. Exp Clin Endocrinol Diabetes. 2001;109(2):87-92. [pmid: 11341304].
Pfitzner MA, Thacher TD, Pettifor JM, et al. Absence of vitamin D deficiency in young Nigerian children. Eur J Pediatr. 1998;133(6):740-744.
Picard D, Imbach A, Couturier M, et al. Longitudinal study of bone density and its determinants in women in peri- or early menopause. Calcif Tissue Int. 2000;67(5):356-360. [pmid: 11136532].
Pietrek J, Otto-Buczkowska E, Kokot F, et al. Concentration of 25-hydroxyvitamin D in serum of infants under the intermittent high-dose vitamin D3 prophylactic treatment. Arch Immunol Ther Exp (Warsz). 1980;28(5):805-814. [pmid: 6260055].
Pietrek J, Preece MA, Windo J, et al. Prevention of vitamin-D deficiency in Asians. Lancet. 1976;1(7970):1145-1148. [pmid: 58197].
Pillow JJ, Forrest PJ, Rodda CP. Vitamin D deficiency in infants and young children born to migrant parents. J Paediatr Child Health. 1995;31(3):180-184. [pmid: 7669375].
Pitson GA, Lugg DJ, Roy CR. Effect of seasonal ultraviolet radiation fluctuations on vitamin D homeostasis during an Antarctic expedition. Eur J Appl Physiol Occup Physiol. 1996;72(3):231-234. [pmid: 8820891].
Pittard WB, Geddes KM, Hulsey TC, et al. How much vitamin D for neonates?. Am J Dis Child. 1991;145(10):1147-1149. [pmid: 1928007].
Poskitt EM, Cole TJ, Lawson DE. Diet, sunlight, and 25-hydroxy vitamin D in healthy children and adults. Br Med J. 1979;1(6158):221-223. [pmid: 311234]. [pmcid: 1597903].
Premaor MO, Alves GV, Crossetti LB, et al. Hyperparathyroidism secondary to hypovitaminosis D in hypoalbuminemic is less intense than in normoalbuminemic patients: a prevalence study in medical inpatients in southern Brazil. Endocrine. 2004;24(1):47-53. [pmid: 15249703].
Prentice A, Yan L, Jarjou LM, et al. Vitamin D status does not influence the breast-milk calcium concentration of lactating mothers accustomed to a low calcium intake. Acta Paediatr. 1997;86(9):1006-1008. [pmid: 9343285].
Prestwood KM, Pannullo AM, Kenny AM, et al. The effect of a short course of calcium and vitamin D on bone turnover in older women. Osteoporos Int. 1996;6(4):314-319. [pmid: 8883121].
Pun KK, Wong FH, Wang C, et al. Vitamin D status among patients with fractured neck of femur in Hong Kong. Bone. 1990;11(5):365-368. [pmid: 2252813].
Quesada JM, Coopmans W, Ruiz B, et al. Influence of vitamin D on parathyroid function in the elderly. J Clin Endocrinol Metab. 1992;75(2):494-501. [pmid: 1639950].
Raghuramulu N, Reddy V. Studies on vitamin D metabolism in malnourished children. Br J Nutr. 1982;47(2):231-234. [pmid: 6279142].
Raghuramulu N, Reddy V. Serum 25-hydroxy-vitamin D levels in malnourished children with rickets. Arch Dis Child. 1980;55(4):285-287. [pmid: 6774669]. [pmcid: 1626835].
Rahman SA, Chee WS, Yassin Z, et al. Vitamin D status among postmenopausal Malaysian women. Asia Pac J Clin Nutr. 2004;13(3):255-260. [pmid: 15331337].
Rajeswari J, Balasubramanian K, Bhatia V, et al. Aetiology and clinical profile of osteomalacia in adolescent girls in northern India. Natl Med J India. 2003;16(3):139-142. [pmid: 12929856].
Rapin CH, Lagier R. Comparative blood chemical data related to aging, femoral neck fracture and hip osteoarthrosis. Z Rheumatol. 1989;48(4):175-181. [pmid: 2800734].
Rapuri PB, Gallagher JC. Effect of Vitamin D supplement use on serum concentrations of total 25OHD levels in elderly women. Journal of Steroid Biochemistry & Molecular Biology. 2004;89–90(15):601-604.
Rapuri PB, Gallagher JC, Haynatzki G. Effect of vitamins D2 and D3 supplement use on serum 25OHD concentration in elderly women in summer and winter. Calcif Tissue Int. 2004;74(2):150-156. [pmid: 14648011].
Rapuri PB, Kinyamu HK, Gallagher JC, et al. Seasonal changes in calciotropic hormones, bone markers, and bone mineral density in elderly women. J Clin Endocrinol Metab. 2002;87(5):2024-2032. [pmid: 11994336].
Rashid A, Mohammed T, Stephens WP, et al. Vitamin D state of Asians living in Pakistan. Br Med J (Clin Res Ed). 1983;286(6360):182-184.
Rassouli A, Milanian I, Moslemi-Zadeh M. Determination of serum 25-hydroxyvitamin D(3) levels in early postmenopausal Iranian women: relationship with bone mineral density. Bone. 2001;29(5):428-430. [pmid: 11704493].
Reginster JY, Deroisy R, Pirenne H, et al. High prevalence of low femoral bone mineral density in elderly women living in nursing homes or community-dwelling: a plausible role of increased parathyroid hormone secretion. Osteoporos Int. 1999;9(2):121-128. [pmid: 10367038].
Rejnmark L, Jorgensen ME, Pedersen MB, et al. Vitamin D insufficiency in Greenlanders on a westernized fare: ethnic differences in calcitropic hormones between Greenlanders and Danes. Calcif Tissue Int. 2004;74(3):255-263. [pmid: 14708040].
Rizzoli R, Stoermann C, Ammann P, et al. Hypercalcemia and hyperosteolysis in vitamin D intoxication: effects of clodronate therapy. Bone. 1994;15(2):193-198. [pmid: 8086237].
Roberts CC, Chan GM, Folland D, et al. Adequate bone mineralization in breast-fed infants. Eur J Pediatr. 1981;99(2):192-196.
Rock CL, Thornquist MD, Kristal AR, et al. Demographic, dietary and lifestyle factors differentially explain variability in serum carotenoids and fat-soluble vitamins: baseline results from the sentinel site of the Olestra Post-Marketing Surveillance Study. Br J Nutr. 1999;129(4):855-864.
Romagnoli E, Caravella P, Scarnecchia L, et al. Hypovitaminosis D in an Italian population of healthy subjects and hospitalized patients. Br J Nutr. 1999;81(2):133-137. [pmid: 10450331].
Rossini M, Alberti V, Flor L, et al. Effect of oral vitamin D2 yearly bolus on hip fracture risk in elderly women: a community primary prevention study. Aging Clin Exp Res. 2004;16(6):432-436. [pmid: 15739592].
Rucker D, Ezzat S, Diamandi A, et al. IGF-I and testosterone levels as predictors of bone mineral density in healthy, community-dwelling men. Clin Endocrinol (Oxf). 2004;60(4):491-499. [pmid: 15049965].
Rudnicki M, Thode J, Jorgensen T, et al. Effects of age, sex, season and diet on serum ionized calcium, parathyroid hormone and vitamin D in a random population. J Intern Med. 1993;234(2):195-200. [pmid: 8340743].
Rushton C. Vitamin D hydroxylation in youth and old age. Age & Ageing. 1978;7(2):91-95. [pmid: 665429].
Ryan P, Dixon T. Prevalence of vitamin D inadequacy in patients attending a metabolic bone clinic in Medway. Curr Med Res Opin. 2006;22(1):211-216. [pmid: 16393446].
Saadi HF, Reed RL, Carter AO, et al. Correlation of quantitative ultrasound parameters of the calcaneus with bone density of the spine and hip in women with prevalent hypovitaminosis D. J Clin Densitom. 2004;7(3):313-318. [pmid: 15319503].
Sachan A, Gupta R, Das V, et al. High prevalence of vitamin D deficiency among pregnant women and their newborns in northern India. Am J Clin Nutr. 2005;81(5):1060-1064. [pmid: 15883429].
Sahota O, Gaynor K, Harwood RH, et al. Hypovitaminosis D and ‘functional hypoparathyroidism’-the NoNoF (Nottingham Neck of Femur) study. Age & Ageing. 2001;30(6):467-472. [pmid: 11742774].
Sahota O, Masud T, San P, et al. Vitamin D insufficiency increases bone turnover markers and enhances bone loss at the hip in patients with established vertebral osteoporosis. Clin Endocrinol (Oxf). 1999;51(2):217-221. [pmid: 10468993].
Sahota O, Mundey MK, San P, et al. The relationship between vitamin D and parathyroid hormone: Calcium homeostasis, bone turnover, and bone mineral density in postmenopausal women with established osteoporosis. Bone. 2004;35(1):312-319. [pmid: 15207772].
Salamone LM, Dallal GE, Zantos D, et al. Contributions of vitamin D intake and seasonal sunlight exposure to plasma 25-hydroxyvitamin D concentration in elderly women. Am J Clin Nutr. 1994;59(1):80-86. [pmid: 8279408].
Saraiva GL, Cendoroglo MS, Ramos LR, et al. Influence of ultraviolet radiation on the production of 25 hydroxyvitamin D in the elderly population in the city of Sao Paulo (23 degrees 34'S), Brazil. Osteoporos Int. 2005;16(12):1649-1654. [pmid: 15947862].
Sato Y, Inose M, Higuchi I, et al. Changes in the supporting muscles of the fractured hip in elderly women. Bone. 2002;30(1):325-330. [pmid: 11792605].
Savolainen K, Maenpaa PH, Alhava EM, et al. A seasonal difference in serum 25-hydroxyvitamin D3 in a Finnish population. Med Biol. 1980;58(1):49-52. [pmid: 7382580].
Scanlon KS, Blank S, Sinks T, et al. Subclinical health effects in a population exposed to excess vitamin D in milk. Am J Public Health. 1995;85(10):1418-1422. [pmid: 7573628]. [pmcid: 1615632].
Scharla SH, Scheidt-Nave C, Leidig G, et al. Lower serum 25-hydroxyvitamin D is associated with increased bone resorption markers and lower bone density at the proximal femur in normal females: a population-based study. Exp Clin Endocrinol Diabetes. 1996;104(3):289-292. [pmid: 8817249].
Scopacasa F, Wishart JM, Horowitz M, et al. Relation between calcium absorption and serum calcitriol in normal men: evidence for age-related intestinal resistance to calcitriol. Eur J Clin Nutr. 2004;58(2):264-269. [pmid: 14749746].
Scotti A, Bianchini C, Abbiati G, et al. Absorption of calcium administered alone or in fixed combination with vitamin D to healthy volunteers. Arzneimittelforschung. 2001;51(6):493-500. [pmid: 11455682].
Scragg R, Holdaway I, Jackson R, et al. Plasma 25-hydroxyvitamin D3 and its relation to physical activity and other heart disease risk factors in the general population. Ann Epidemiol. 1992;2(5):697-703. [pmid: 1342321].
Scragg R, Holdaway I, Singh V, et al. Serum 25-hydroxyvitamin D3 is related to physical activity and ethnicity but not obesity in a multicultural workforce. Aust N Z J Med. 1995;25(3):218-223. [pmid: 7487689].
Scragg R, Khaw KT, Murphy S. Life-style factors associated with winter serum 25-hydroxyvitamin D levels in elderly adults. Age & Ageing. 1995;24(4):271-275. [pmid: 7484480].
Sedrani S H, Reprint author, Abanmy A et al. Vitamin D status of Saudis: V. Are Saudi children at risk of developing vitamin D deficiency rickets? Saudi Med J 1992;13(5):430–433.
Sedrani SH, Al Arabi K, Abanmy A, et al. Vitamin D status of Saudis: IV. Seasonal variations. Saudi Med J. 1992;13(5):423-429.
Sedrani SH, Al Arabi K, Abanmy A, et al. Vitamin D status of Saudis II : effect of regional and environmental location. Saudi Med J. 1992;13(3):206-213.
Sedrani SH, Elidrissy AW, El Arabi KM. Sunlight and vitamin D status in normal Saudi subjects. Am J Clin Nutr. 1983;38(1):129-132. [pmid: 6602540].
Sem S W, Sjoen R J, Trygg K et al. Vitamin D status of two groups of elderly in Oslo: living in old people's homes and living in own homes. Compr Gerontol [C] 1987;Section A, Clinical & Laboratory Sciences. 1(3):126–130.
Semba RD, Garrett E, Johnson BA, et al. Vitamin D deficiency among older women with and without disability. Am J Clin Nutr. 2000;72(6):1529-1534. [pmid: 11101482].
Serenius F, Elidrissy AT, Dandona P. Vitamin D nutrition in pregnant women at term and in newly born babies in Saudi Arabia. J Clin Pathol. 1984;37(4):444-447. [pmid: 6608533]. [pmcid: 498748].
Serhan E, Holland MR. Calcium and vitamin D supplementation failed to improve bone mineral density in Indo-Asians suffering from hypovitaminosis D and secondary hyperparathyroidism. Rheumatol Int. 2005;25(4):276-279. [pmid: 14727056].
Seton M, Jackson V, Lasser KE, et al. Low 25-hydroxyvitamin D and osteopenia are prevalent in persons > or =55 yr with fracture at any site: a prospective, observational study of persons fracturing in the community. J Clin Densitom. 2005;8(4):454-460. [pmid: 16311431].
Shany S, Chaimovitz C, Yagev R, et al. Vitamin D-deficiency in the elderly: treatment with ergocalciferol and hydroxylated analogues of vitamin D3. Isr J Med Sci. 1988;24(3):160-163. [pmid: 3259568].
Shaunak S, Colston K, Ang L, et al. Vitamin D deficiency in adult British Hindu Asians: a family disorder. Br Med J (Clin Res Ed). 1985;291(6503):1166-1168.
Sheltawy M, Newton H, Hay A, et al. The contribution of dietary vitamin D and sunlight to the plasma 25-hydroxyvitamin D in the elderly. Hum Nutr Clin Nutr. 1984;38(3):191-194. [pmid: 6611327].
Sherman SS, Tobin JD, Hollis BW, et al. Biochemical parameters associated with low bone density in healthy men and women. J Bone Miner Res. 1992;7(10):1123-1130. [pmid: 1456082].
Shuster S, Chadwick L, Afacan AS, et al. Serum 25-hydroxy vitamin D in coalworkers and surface workers in winter. Br Med J (Clin Res Ed). 1982;284(6313):386.
Shuster S, Chadwick L, Afacan AS, et al. Serum 25-hydroxy vitamin D in surface and underground coalminers. Br Med J (Clin Res Ed). 1981;283(6284):106.
Sigurdsson G, Franzson L, Steingrimsdottir L, et al. The association between parathyroid hormone, vitamin D and bone mineral density in 70-year-old Icelandic women. Osteoporos Int. 2000;11(12):1031-1035. [pmid: 11256894].
Smerdely P, Seller M, Smith A, et al. Predictors of bone mass in healthy older men in the community. Med J Aust. 2000;173(4):183-186. [pmid: 11008590].
Somerville PJ, Lien JW, Kaye M. The calcium and vitamin D status in an elderly female population and their response to administered supplemental vitamin D3. J Gerontol. 1977;32(6):659-663. [pmid: 199641].
Soontrapa S, Soontrapa S, Pongchaiyakul C, et al. Prevalence of hypovitaminosis D in elderly women living in urban area of Khon Kaen province, Thailand. J Med Assoc Thai. 2001;84(Suppl):2S534-S541.
Souberbielle JC, Cormier C, Kindermans C, et al. Vitamin D status and redefining serum parathyroid hormone reference range in the elderly. J Clin Endocrinol Metab. 2001;86(7):3086-3090. [pmid: 11443171].
Sowers MR, Wallace RB, Hollis BW, et al. Parameters related to 25-OH-D levels in a population-based study of women. Am J Clin Nutr. 1986;43(4):621-628. [pmid: 3485918].
Specker BL, Tsang RC. Cyclical serum 25-hydroxyvitamin D concentrations paralleling sunshine exposure in exclusively breast-fed infants. Eur J Pediatr. 1987;110(5):744-747.
Specker BL, Tsang RC, Hollis BW. Effect of race and diet on human-milk vitamin D and 25-hydroxyvitamin D. Am J Dis Child. 1985;139(11):1134-1137. [pmid: 2998180].
Specker BL, Tsang RC, Ho M, et al. Seasonal differences in serum vitamin D binding protein in exclusively breast-fed infants: negative relationship to sunshine exposure and 25-hydroxyvitamin D. J Pediatr Gastroenterol Nutr. 1986;5(2):290-294. [pmid: 3958856].
Specker BL, Valanis B, Hertzberg V, et al. Sunshine exposure and serum 25-hydroxyvitamin D concentrations in exclusively breast-fed infants. Eur J Pediatr. 1985;107(3):372-376.
Spindler A, Lucero E, Berman A, et al. Bone mineral density in a native population of Argentina with low calcium intake. Br J Rheumatol. 1995;22(11):2148-2151.
Staberg B, Christiansen C, Rossing N. Serum vitamin D metabolites in normal subjects after phototherapy. Scand J Clin Lab Invest. 1984;44(1):53-56. [pmid: 6608135].
Stamp TC, Haddad JG, Twigg CA. Comparison of oral 25-hydroxycholecalciferol, vitamin D, and ultraviolet light as determinants of circulating 25-hydroxyvitamin D. Lancet. 1977;1(8026):1341-1343. [pmid: 69059].
Stein EM, Laing EM, Hall DB, et al. Serum 25-hydroxyvitamin D concentrations in girls aged 4–8 y living in the southeastern United States. Am J Clin Nutr. 2006;83(1):75-81. [pmid: 16400053].
Stein MS, Flicker L, Scherer SC, et al. Relationships with serum parathyroid hormone in old institutionalized subjects. Clin Endocrinol (Oxf). 2001;54(5):583-592. [pmid: 11380488].
Stephens WP, Klimiuk PS, Warrington S, et al. Observations on the dietary practices of Asians in the United Kingdom. Hum Nutr Appl Nutr. 1982;36(6):438-444. [pmid: 7161136].
Stern PH, Taylor AB, Bell NH, et al. Demonstration that circulating 1 alpha, 25-dihydroxyvitamin D is loosely regulated in normal children. Eur J Clin Invest. 1981;68(5):1374-1377.
Sullivan SS, Rosen CJ, Halteman WA, et al. Adolescent girls in Maine are at risk for vitamin D insufficiency. J Am Diet Assoc. 2005;105(6):971-974. [pmid: 15942551].
Suzuki Y, Davison KS, Chilibeck PD. Total calcium intake is associated with cortical bone mineral density in a cohort of postmenopausal women not taking estrogen. J Nutr Health Aging. 2003;7(5):296-299. [pmid: 12917743].
Szulc P, Munoz F, Marchand F, et al. Role of vitamin D and parathyroid hormone in the regulation of bone turnover and bone mass in men: the MINOS study. Calcif Tissue Int. 2003;73(6):520-530. [pmid: 12958693].
Taha W, Chin D, Silverberg AI, et al. Reduced spinal bone mineral density in adolescents of an Ultra-Orthodox Jewish community in Brooklyn. Pediatrics. 2001;107(5):E79. [pmid: 11331729].
Takeuchi A, Okano T, Ishida Y, et al. Effects of dietary vitamin D intake on plasma levels of parathyroid hormone and vitamin D metabolites in healthy Japanese. Miner Electrolyte Metab. 1995;21(13):217-222. [pmid: 7565453].
Takeuchi A, Okano T, Tsugawa N, et al. Effects of ergocalciferol supplementation on the concentration of vitamin D and its metabolites in human milk. Br J Nutr. 1989;119(11):1639-1646.
Tamatani M, Morimoto S, Nakajima M, et al. Decreased circulating levels of vitamin K and 25-hydroxyvitamin D in osteopenic elderly men. Metab Clin Exp. 1998;47(2):195-199. [pmid: 9472970].
Tandon N, Marwaha RK, Kalra S, et al. Bone mineral parameters in healthy young Indian adults with optimal vitamin D availability.[see comment]. Natl Med J India. 2003;16(6):298-302. [pmid: 14765619].
Tangpricha V, Pearce EN, Chen TC, et al. Vitamin D insufficiency among free-living healthy young adults. Am J Med. 2002;112(8):659-662. [pmid: 12034416].
Tangpricha V, Turner A, Spina C, et al. Tanning is associated with optimal vitamin D status (serum 25-hydroxyvitamin D concentration) and higher bone mineral density. Am J Clin Nutr. 2004;80(6):1645-1649. [pmid: 15585781].
Tareen N, Martins D, Zadshir A, et al. The impact of routine vitamin supplementation on serum levels of 25 (OH) D3 among the general adult population and patients with chronic kidney disease. Ethn Dis. 2005;15(4 Suppl 5):S5-S6.
Taylor AF, Norman ME. Vitamin D metabolite levels in normal children. Pediatr Res. 1984;18(9):886-890. [pmid: 6333015].
Theiler R, Bischoff H, Tyndall A, et al. Elevated PTH levels in hypovitaminosis D are more rapidly suppressed by the administration of 1,25-dihydroxy-vitamin D3 than by vitamin D3. Int J Vitam Nutr Res. 1998;68(1):36-41. [pmid: 9503046].
Theiler R, Stahelin HB, Kranzlin M, et al. Influence of physical mobility and season on 25-hydroxyvitamin D-parathyroid hormone interaction and bone remodelling in the elderly. Eur J Endocrinol. 2000;143(5):673-679. [pmid: 11078992].
Theiler R, Stahelin HB, Kranzlin M, et al. High bone turnover in the elderly. Arch Phys Med Rehabil. 1999;80(5):485-489. [pmid: 10326908].
Theiler R, Stahelin HB, Tyndall A, et al. Calcidiol, calcitriol and parathyroid hormone serum concentrations in institutionalized and ambulatory elderly in Switzerland. Int J Vitam Nutr Res. 1999;69(2):96-105. [pmid: 10218146].
Thomson K, Morley R, Grover SR, et al. Postnatal evaluation of vitamin D and bone health in women who were vitamin D-deficient in pregnancy, and in their infants. Med J Aust. 2004;181(9):486-488. [pmid: 15516192].
Tjellesen L, Christiansen C. Vitamin D metabolites in normal subjects during one year. A longitudinal study. Scand J Clin Lab Invest. 1983;43(1):85-89. [pmid: 6604936].
Toss G, Larsson L, Lindgren S. Serum levels of 25-hydroxyvitamin D in adults and elderly humans after a prophylactic dose of vitamin D2. Scand J Clin Lab Invest. 1983;43(4):329-332. [pmid: 6605572].
Tsai KS, Chen JS, Hwang KM, et al. Age-related changes in vitamin D metabolites, osteocalcin, alkaline phosphatase and parathyrin in normal Chinese women in Taipei. J Formos Med Assoc. 1991;90(11):1033-1037. [pmid: 1687046].
Tsai KS, Hsu SH, Cheng JP, et al. Vitamin D stores of urban women in Taipei: effect on bone density and bone turnover, and seasonal variation. Bone. 1997;20(4):371-374. [pmid: 9108358].
Tsai KS, Wahner HW, Offord KP, et al. Effect of aging on vitamin D stores and bone density in women. Calcif Tissue Int. 1987;40(5):241-243. [pmid: 3107776].
Turton CW, Stanley P, Stamp TC, et al. Altered vitamin-D metabolism in pregnancy. Lancet. 1977;1(8005):222-225. [pmid: 64751].
Ulivieri FM, Verdoia C, Ortolani S, et al. Vitamin D concentrations in women of postmenopausal age with fractures of the femoral neck. Italian Journal of Orthopaedics & Traumatology. 1986;12(3):401-405. [pmid: 3570759].
Valimaki VV, Alfthan H, Lehmuskallio E, et al. Vitamin D status as a determinant of peak bone mass in young Finnish men. J Clin Endocrinol Metab. 2004;89(1):76-80. [pmid: 14715830].
van der Wielen RP, Lowik MR, et al. Serum vitamin D concentrations among elderly people in Europe. Lancet. 1995;346(8969):207-210. [pmid: 7616799].
van der Sluis I, Hop WC, et al. A cross-sectional study on biochemical parameters of bone turnover and vitamin d metabolites in healthy dutch children and young adults. Horm Res. 2002;57(56):170-179. [pmid: 12053089].
Varghese M, Rodman JS, Williams JJ, et al. The effect of ultraviolet B radiation treatments on calcium excretion and vitamin D metabolites in kidney stone formers. Clin Nephrol. 1989;31(5):225-231. [pmid: 2736812].
Vecino-Vecino C, Gratton M, Kremer R, et al. Seasonal variance in serum levels of vitamin D determines a compensatory response by parathyroid hormone: Study in an ambulatory elderly population in Quebec. Gerontology. 2006;52(1):33-39. [pmid: 16439822].
Verity CM, Burman D, Beadle PC, et al. Seasonal changes in perinatal vitamin D metabolism: maternal and cord blood biochemistry in normal pregnancies. Arch Dis Child. 1981;56(12):943-948. [pmid: 7332342]. [pmcid: 1627487].
Vieth R, Cole DE, Hawker GA, et al. Wintertime vitamin D insufficiency is common in young Canadian women, and their vitamin D intake does not prevent it. Eur J Clin Nutr. 2001;55(12):1091-1097. [pmid: 11781676].
Vik T, Try K, Stromme JH. The vitamin D status of man at 70 degrees north. Scand J Clin Lab Invest. 1980;40(3):227-232. [pmid: 7444339].
von Knorring J, Slatis P, Weber TH, et al. Serum levels of 25-hydroxyvitamin D, 24,25-dihydroxyvitamin D and parathyroid hormone in patients with femoral neck fracture in southern Finland. Clin Endocrinol (Oxf). 1982;17(2):189-194. [pmid: 6982127].
von Muhlen D G, Greendale G A, Garland C F et al. Vitamin D, parathyroid hormone levels and bone mineral density in community-dwelling older women: The Rancho Bernardo Study. Osteoporos Int 2005;Epub
von Muhlen DG, Greendale GA, Garland CF, et al. Vitamin D, parathyroid hormone levels and bone mineral density in community-dwelling older women: the Rancho Bernardo Study. Osteoporos Int. 2005;16(12):1721-1726. [pmid: 15928802].
Waiters B, Godel JC, Basu TK. Perinatal vitamin D and calcium status of northern Canadian mothers and their newborn infants. J Am Coll Nutr. 1999;18(2):122-126. [pmid: 10204827].
Webb AR, Pilbeam C, Hanafin N, et al. An evaluation of the relative contributions of exposure to sunlight and of diet to the circulating concentrations of 25-hydroxyvitamin D in an elderly nursing home population in Boston. Am J Clin Nutr. 1990;51(6):1075-1081. [pmid: 2349922].
Webb AR, Steven MD, Hosking DJ, et al. Correction of vitamin D deficiency in elderly long-stay patients by sunlight exposure. Journal of Nutritional Medicine. 1990;1(3):201-208.
Weiler H, Fitzpatrick-Wong S, Veitch R, et al. Vitamin D deficiency and whole-body and femur bone mass relative to weight in healthy newborns.[see comment]. CMAJ. 2005;172(6):757-761. [pmid: 15767609]. [pmcid: 552889].
Weisman Y, Schen RJ, Eisenberg Z, et al. Inadequate status and impaired metabolism of vitamin D in the elderly. Isr J Med Sci. 1981;17(1):19-21. [pmid: 6257624].
Whyte MP, Haddad JG, Walters DD, et al. Vitamin D bioavailability: serum 25-hydroxyvitamin D levels in man after oral, subcutaneous, intramuscular, and intravenous vitamin D administration. J Clin Endocrinol Metab. 1979;48(6):906-911. [pmid: 447796].
Woitge HW, Scheidt-Nave C, Kissling C, et al. Seasonal variation of biochemical indexes of bone turnover: results of a population-based study. J Clin Endocrinol Metab. 1998;83(1):68-75. [pmid: 9435418].
Wortsman J, Matsuoka LY, Chen TC, et al. Decreased bioavailability of vitamin D in obesity. Am J Clin Nutr. 2000;72(3):690-693. [pmid: 10966885].
Wu F, Staykova T, Horne A, et al. Efficacy of an oral, 10-day course of high-dose calciferol in correcting vitamin D deficiency. N Z Med J. 2003;116(1179):U536. [pmid: 14513083].
Yan L, Prentice A, Zhang H, et al. Vitamin D status and parathyroid hormone concentrations in Chinese women and men from north-east of the People's Republic of China. Eur J Clin Nutr. 2000;54(1):68-72. [pmid: 10694775].
Yonei T, Hagino H, Katagiri H, et al. Bone metabolic changes in Antarctic wintering team members. Bone. 1999;24(2):145-150. [pmid: 9951785].
Zamboni M, Zoico E, Tosoni P, et al. Relation between vitamin D, physical performance, and disability in elderly persons. J Gerontol A Biol Sci Med Sci. 2002;57(1):M7-11. [pmid: 11773206].
Zerath E, Holy X, Gaud R, et al. Decreased serum levels of 1,25-(OH)2 vitamin D during 1 year of sunlight deprivation in the Antarctic. Eur J Appl Physiol Occup Physiol. 1999;79(2):141-147. [pmid: 10029334].
Zerwekh JE, Sakhaee K, Glass K, et al. Long term 25-hydroxyvitamin D3 therapy in postmenopausal osteoporosis: demonstration of responsive and nonresponsive subgroups. J Clin Endocrinol Metab. 1983;56(2):410-413. [pmid: 6600460].
Zhang Z-L, Qin Y-J, Huang Q-R, et al. Association of estrogen receptor-alpha and vitamin D receptor genotypes with therapeutic response to calcium in postmenopausal Chinese women. Acta Pharmacol Sin. 2004;25(12):1690-1697. [pmid: 15569417].
Zhu K, Zhang Q, Foo LH, et al. Growth, bone mass, and vitamin D status of Chinese adolescent girls 3 y after withdrawal of milk supplementation. Am J Clin Nutr. 2006;83(3):714-721. [pmid: 16522922].
Zittermann A, Scheld K, Stehle P. Seasonal variations in vitamin D status and calcium absorption do not influence bone turnover in young women. Eur J Clin Nutr. 1998;52(7):501-506. [pmid: 9683332].
Zochling J, Chen JS, Seibel M, et al. Calcium metabolism in the frail elderly. Clin Rheumatol. 2005;24(6):576-582. [pmid: 16082497].
Zochling J, Sitoh YY, Lau TC, et al. Quantitative ultrasound of the calcaneus and falls risk in the institutionalized elderly: sex differences and relationship to vitamin D status. Osteoporos Int. 2002;13(11):882-887. [pmid: 12415435].
Zofkova I, Bahbouh R, Bendlova B, et al. Circulating beta(2) microglobulin in relation to bone metabolism: implications for bone loss with aging. Calcif Tissue Int. 1999;65(6):442-446. [pmid: 10594162].