# Appendix A. Search Strategies

Medline strategy: [variations of these strategies exist for a) Embase, b) CENTRAL CINAHL AMED, c) Biological abstracts]

1 (25-hydroxy vit D or 25-hydroxy vit d or Plasma vit D).tw.
2 64719-49-9.rn.
3 25OHD3.tw.
4 “25(OH)D3”.tw.
5 25-OHD3.tw.
6 “25-(OH)D3”.tw.
7 25OHD.tw.
8 “25(OH)D”.tw.
9 25-OHD.tw.
10 “25-(OH)D”.tw.
11 25-hydroxycholecalciferol.tw.
12 calcidiol.tw.
13 Calcifediol/
14 or/1–13
15 Rickets/
16 rachitis.tw.
17 rickets.tw.
18 Bone Density/
19 exp Osteoporosis/
20 ((bone$ or plate$) adj3 mineral$).tw.
21 (bone adj2 (loss or turnover or densi$)).tw.
22 (Skelet$ adj2 (mineral$ or development$)).tw.
23 mineralization defect$.tw.
24 Mineral$ content$.tw.
25 BMC.tw.
26 Osteoporo$.tw.
27 Osteomalac$.tw.
28 Osteopath$.tw.
29 Bone Development/
30 Osteogenesis/
31 exp Fractures/
32 fracture$.tw.
33 Accidental Falls/
34 falls.tw.
35 exp “Bone and Bones”/
36 Calcium/
37 Intestinal Absorption/
38 (calcium adj3 absorb$).tw.
39 36 and absorb$.tw.
40 36 and 37
41 or/38–40
42 Parathyroid hormone/
43 parathyroid hormone$.tw.
44 Serum PTH.tw.
45 (“PTH (1–84)” or “pth(1–84)”).tw.
46 or/15–35,41–45
47 Nutritive Value/
48 Diet/
49 exp Maternal Nutrition/
50 exp Infant nutrition/
51 (Diet$ or nutrition$).tw.
52 Dietary Supplements/
53 Food, Fortified/
54 (fortifi$ or supplement$).tw.
55 exp Vit d/
56 (vit adj (d or d2 or d3)).mp.
57 (or/52–54) and (or/55–56)
58 (or/47–54) and (or/55–56)
59 ((oral or iu) adj2 vit adj (d or d3)).tw.
60 Ergocalciferols/
61 Ergocalciferol$.tw.
62 Cholecalciferol/
63 Cholecalciferol$.tw.
64 calciferol.tw.
65 Vit D Deficiency/dh, dt
66 exp Vit D/ad
67 or/58–66
68 Sunlight/
69 Heliotherapy/
70 Skin Pigmentation/
71 (sun or sunlight$).tw.
72 cutaneous exposure.tw.
73 (ultraviolet or uvb or uv b).tw.
74 (latitude$ or geograph$ or pigment$).tw.
75 Seasons/
76 season$.tw.
77 Homebound Persons/
78 (shut in$ or home bound or house bound).tw.
79 or/58–66,68–78
80 or/31–34
81 Vit D/to [Toxicity]
82 No-Observed-Adverse-Effect Level/
83 upper limit$.tw.
84 UL.tw.
85 (excess$ or toxic$).tw.
86 vit d intox$.tw.
87 (noael or noel).tw.
88 (no observed adj2 effect$).tw.
89 Calcification, Physiologic/de [Drug Effects]
90 Hypercalcemia/
91 Kidney Calculi/
92 Nephrocalcinosis/
93 Urinary Calculi/
94 Bladder Calculi/
95 Ureteral Calculi/
96 Calcinosis/
97 Hypercalcemi$.tw.
98 (Burnett$ adj2 syndrome$).tw.
99 Hypercalciuri$.tw.
100 or/81–99
101 14 and 46
102 14 and 79
103 RANDOMIZED CONTROLLED TRIAL.pt.
104 CONTROLLED CLINICAL TRIAL.pt.
105 RANDOMIZED CONTROLLED TRIALS.sh.
106 RANDOM ALLOCATION.sh.
107 DOUBLE BLIND METHOD.sh.
108 SINGLE-BLIND METHOD.sh.
109 or/103–108.
110 (ANIMALS not HUMAN).sh.
111 109 not 110
112 CLINICAL TRIAL.pt.
113 exp CLINICAL TRIALS/
114 (clin$ adj25 trial$).ti,ab.
115 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
116 PLACEBOS.sh.
117 placebo$.ti,ab.
118 random$.ti,ab.
119 versus.tw.
120 RESEARCH DESIGN.sh.
121 or/112–120
122 121 not 110
123 122 not 111
124 111 or 123
125 (or/57,59–66) and 80 and 124
126 67 and 100
127 101 or 102 or 125 or 126
128 limit 127 to animals
129 limit 128 to humans
130 not (128 not 129)