# Appendixes

Appendix A. Search Strategies

Appendix B. Screening, Data Abstraction, and Quality Assessment Forms

Appendix C. Statistics Information Form

Appendix D. Quality Assessment of RCTs

Appendix E. Reference List - Quality Assessment of RCTs

Appendix F. Additional Data Provided by Study Authors

Appendix G. List of Unobtained Articles

Appendix H. Additional Acknowledgments

Appendix I. List of Excluded Studies at Full-Text Screening (Level 2 screening)

Appendix J. List of Excluded Studies on the Basis Study Design (Level 3 screening)