# List of Acronyms/Abbreviations

? | unknown; unclear
1° | primary
2° | secondary
A | arthroscopy
Acet | acetaminophen
ACR | American College of Rheumatology
ADL | Activities of Daily Living
ADL | arthroscopy, lavage, and debridement
AE(s) | adverse events
AL | arthroscopy and lavage
ARA | American Rheumatism Association
BMI | body mass index
CI | confidence interval
D | debridement
dis | disease
FE | fixed effects
GH | glucosamine hydrochloride
GS | glucosamine sulfate
HSS | Hospital for Special Surgery
IA | intra-articular
ITT | intention-to-treat
JSN | joint space narrowing
K-L | Kellgren-Lawrence
L | lavage
LI | Lequesne Index
MA(s) | meta-analysis(es)
mn | mean
mo(s) | month(s)
N | number
n | number
N | no
NR | not reported
NS | nonsignificant
NSAID(s) | nonsteroidal anti-inflammatory drug(s)
NSD | no significant difference
OA | osteoarthritis
OAK | osteoarthritis of the knee
OMERACT-OARSI | Outcomes Measures in Rheumatology Clinical Trials-Osteoarthritis Research Society
Pl | placebo
PT | physical therapy
pts | patients
RCT(s) | randomized, controlled trial(s)
RE | random effects
rng | range
RR | relative risk
sd | standard deviation
SEM | standard error of the mean
SMD | standardized mean difference
Tx | treatment
USPSTF | U.S. Preventive Services Task Force
VAS | visual analog scale
WMD | weighted mean difference
WOMAC | Western Ontario and McMaster Universities Osteoarthritis Index
Y | yes
yr(s) | year(s)