# References

Aaron RK, Skolnick AH, Reinert SE, et al. Arthroscopic debridement for osteoarthritis of the knee. J Bone Joint Surg Am. 2006;88(5):936-43. [pmid: 16651566].
Ahlback S. Osteoarthrosis of the knee. A radiographic investigation. Acta Radiol Diagn (Stockh) 1968;Suppl 277:7–72.
Aichroth PM, Patel DV, Moyes ST. A prospective review of arthroscopic debridement for degenerative joint disease of the knee. Int Orthop. 1991;15(4):351-5. [pmid: 1809718].
Altman R, Asch E, Bloch D, et al. Development of criteria for the classification and reporting of osteoarthritis: classification of osteoarthritis of the knee. Arthritis Rheum. 1986;29(8):1039-49. [pmid: 3741515].
Altman RD, Abramson S, Bruyere O, et al. Commentary: osteoarthritis of the knee and glucosamine. Osteoarthritis Cartilage. 2006;14(10):963-6. [pmid: 16857394].
Altman RD, Akermark C, Beaulieu AD, et al. Efficacy and safety of a single intra-articular injection of non-animal stabilized hyaluronic acid (NASHA) in patients with osteoarthritis of the knee. Osteoarthritis Cartilage. 2004;12(8):642-9. [pmid: 15262244].
Altman RD, Moskowitz R. Intraarticular sodium hyaluronate (Hyalgan) in the treatment of patients with osteoarthritis of the knee: a randomized clinical trial. Hyalgan Study Group. J Rheumatol. 1998;25(11):2203-12. [pmid: 9818665].
American Academy of Orthopaedic Surgeons. Osteoarthritis of the knee: state of the condition. 2004. Available at www.aaos.org/Research/documents/OAinfo_knee_state.pdf. Accessed November 2006.
American College of Rheumatology (Subcommittee on Osteoarthritis Guidelines). Recommendations for the medical management of osteoarthritis of the hip and knee. Arthritis Rheum. 2000;43:1905-1915. [pmid: 11014340].
Anderson JW, Nicolosi RJ, Borzelleca JF. Glucosamine effects in humans: A review of effects on glucose metabolism, side effects, safety considerations and efficacy. Food Chem Toxicol. 2005;43:187-201. [pmid: 15621331].
Arrich J, Piribauer F, Mad P, et al. Intra-articular hyaluronic acid for the treatment of osteoarthritis of the knee: systematic review and meta-analysis. CMAJ. 2005;172(8):1039-43. [pmid: 15824412]. [pmcid: 556045].
Balint G, Szebenyi B. Diagnosis of osteoarthritis: guidelines and current pitfalls. Drugs. 1996;52(suppl 3):1-13. [pmid: 8911794].
Bana G, Jamard B, Verrouil E, et al. Chondroitin sulfate in the management of hip and knee osteoarthritis: an overview. Adv Pharmacol. 2006;53:507-22. [pmid: 17239784].
Bellamy N. Musculoskeletal clinical metrology. United Kingdom: Kluwer Academic Publishers; 1993. pp. 193–251.
Bellamy N, Buchanan WW, Goldsmith CH, et al. Validation study of WOMAC: a health status instrument for measuring clinically important patient relevant outcomes to antirheumatic drug therapy in patients with osteoarthritis of the hip or knee. J Rheumatol. 1988;15(12):1833-40. [pmid: 3068365].
Bellamy N, Campbell J, Robinson V, et al. Viscosupplementation for the treatment of osteoarthritis of the knee. Cochrane Database Syst Rev 2006;(2):CD005321.
Bellamy N, Campbell J, Robinson V, et al. Viscosupplementation for the treatment of osteoarthritis of the knee. Cochrane Database Syst Rev 2007;(2):CD005321.
Bernard J, Lemon M, Patterson MH. Arthroscopic washout of the knee—a 5-year survival analysis. Knee. 2004;11(3):233-5. [pmid: 15194101].
Bert JM, Maschka K. The arthroscopic treatment of unicompartmental gonarthrosis: a five-year follow-up study of abrasion arthroplasty plus arthroscopic debridement and arthroscopic debridement alone. Arthroscopy. 1989;5(1):25-32. [pmid: 2706048].
Biggee BA, McAlindon T. Glucosamine for osteoarthritis: part I, review of the clinical evidence. Med Health R I. Jun. 2004;87(6):176-179. [pmid: 15344672].
Bjordal JM, Klovning A, Ljunggren AE, et al. Short-term efficacy of pharmacotherapeutic interventions in osteoarthritic knee pain: a meta-analysis of randomised placebo-controlled trials. Eur J Pain 2006 May 6;[Epub ahead of print].
Blacher RS. Arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(21):1717-9. [pmid: 12448432].
Blue Cross and Blue Shield Association. Special report: Intra-articular hyaluronan for osteoarthritis of the knee. TEC Assessments. 2005;19(17):1-16.
Bohnsack M, Lipka W, Ruhmann O, et al. The value of knee arthroscopy in patients with severe radiological osteoarthritis. Arch Orthop Trauma Surg. 2002;122(8):451-3. [pmid: 12442182].
Bourgeois P, Chales G, Dehais J, et al. Efficacy and tolerability of chondroitin sulfate 1200 mg/day vs chondroitin sulfate 3 × 400 mg/day vs placebo. Osteoarthritis Cartilage. 1998;6(Suppl A):25-30. [pmid: 9743816].
Bragantini A, Cassini MD, Perbellini A. Controlled single-blind trial of intra-articularly injected hyaluronic acid (Hyalgan®) in osteoarthritis of the knee. Clin Trials J. 1987;24(4):333-40.
Brandt KD, Block JA, Michalski JP, et al. Efficacy and safety of intraarticular sodium hyaluronate in knee osteoarthritis. ORTHOVISC Study Group. Clin Orthop Relat Res 2001;(385):130–43.
Brown P, Brunnhuber K, Chalkidou K, et al. How to formulate research recommendations. BMJ. 2006;333(7572):804-6. [pmid: 17038740]. [pmcid: 1602035].
Bucsi L, Poor G. Efficacy and tolerability of oral chondroitin sulfate as a symptomatic slow-acting drug for osteoarthritis (SYSADOA) in the treatment of knee osteoarthritis. Osteoarthritis Cartilage. 1998;6(Suppl A):31-6. [pmid: 9743817].
Bunyaratavej N, Chan KM, Subramanian N. Treatment of painful osteoarthritis of the knee with hyaluronic acid. Results of a multicenter Asian study. J Med Assoc Thai. 2001;84(Suppl 2):S576-81. [pmid: 11853284].
Campbell WJ, Patterson CC. Quantifying meaningful changes in pain. Anesthesia. 1998;53:121-125.
Carey TS, Boden SD. A critical guide to case series reports. Spine. 2003;28(15):1631-1634. [pmid: 12897483].
Carrabba M, Paresce E, Angelini M, et al. The safety and efficacy of different dose schedules of hyaluronic acid in the treatment of painful osteoarthritis of the knee with joint effusion. Eur J Rheumatol Inflamm. 1995;15(1):25-31.
Centers for Disease Control and Prevention. Update: direct and indirect costs of arthritis and other rheumatic conditions—United States, 1997. MMWR Morb Mortal Wkly Rep. 2004;53:388-389. [pmid: 15138399].
Centers for Disease Control and Prevention. Racial/ethnic differences in the prevalence and impact of doctor-diagnosed arthritis—United States, 2002. MMWR Morb Mortal Wkly Rep. 2005;54(5):119-23. Available at www.cdc.gov/mmwr/preview/mmwrhtml/mm5601a2.htm?s_cid=mm5601a2_e. Accessed April 2007. [pmid: 15703693].
Centers for Disease Control and Prevention. Prevalence of doctor-diagnosed arthritis and arthritis-attributable activity limitation—United States, 2003-2005. MMWR Morb Mortal Wkly Rep. 2006;55(40):1089-92. Available at www.cdc.gov/mmwr/preview/mmwrhtml/mm5540a2.htm?s_cid=mm5540a2_e. Last accessed April 2007. [pmid: 17035926].
Centers for Disease Control and Prevention. National and state medical expenditures and lost earnings attributable to arthritis and other rheumatic conditions—United States, 2003. MMWR Morb Mortal Wkly Rep. 2007;56(1):4-7. Available at www.cdc.gov/mmwr/preview/mmwrhtml/mm5405a3.htm. Accessed April 2007. [pmid: 17218935].
Chalmers TC, Smith H Jr, Blackburn, et al. A method for assessing the quality of a randomized control trial. Control Clin Trials. 1981;2(1):31-49. [pmid: 7261638].
Chambers K, Schulzer M, Sobolev B. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. Arthroscopy. 2002;18(7):683-7. [pmid: 12240636].
Chambers KG, Schulzer M. Arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(21):1717-9. [pmid: 12448431].
Cibere J. Do we need radiographs to diagnose osteoarthritis?. Best Practice Res Clin Rheumatol. 2006;20(1):27-38.
Cibere J, Kopec JA, Thorne A, et al. Randomized, double-blind, placebo-controlled glucosamine discontinuation trial in knee osteoarthritis. Arthritis Rheum. 2004;51(5):738-45. [pmid: 15478160].
Claessens AA, Schouten JS, van den Ouweland FA, et al. Do clinical findings associate with radiographic osteoarthritis of the knee?. Ann Rheum Dis. 1990;49:771-774. [pmid: 2241266]. [pmcid: 1004229].
Clarke HD, Scott WN. The role of debridement: through small portals. J Arthroplasty. Apr. 2003;18(3 Suppl 1):10-13. [pmid: 12730920].
Clegg DO, Reda DJ, Harris CL, et al. Glucosamine, chondroitin sulfate, and the two in combination for painful knee osteoarthritis. N Engl J Med. 2006;354(8):795-808. [pmid: 16495392].
Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale, NJ: Erlbaum; 1988.
Cohen M, Wolfe R, Mai T. A randomised, double-blind, placebo-controlled trial of topical glucosamine and chondroitin sulfate for osteoarthritis of the knee [abstract]. Int Med J. 2003;33(3):A17.
Cohen MA, Shiroky JB, Ballachey ML, et al. Double-blind randomized trial of intra-articular (I/A) hyaluronate in the treatment of osteoarthritis of the knee. Arthritis Rheum. 1994;37(Suppl 6):R31.
Conrozier T, Vignon E. Die wirkung von chondroitinsulfat bei der behandlung der huftgelenksarthrose eine doppelblindstudie gegen placebo. Litera Rheumatologica. 1992;14:69-75.
Conrozier T. [Anti-arthrosis treatments: efficacy and tolerance of chondroitin sulfates (CS 4&6)]. Presse Med. 1998;27(36):1862-5. [pmid: 9856136].
Creamer P, Sharif M, George E, et al. Intra-articular hyaluronic acid in osteoarthritis of the knee: an investigation into mechanisms of action. Osteoarthritis Cartilage. 1994;2(2):133-40. [pmid: 11548229].
Crolle G, D'Este E. Glucosamine sulphate for the management of arthrosis: a controlled clinical investigation. Curr Med Res Opin. 1980;7(2):104-9. [pmid: 7002478].
Cubukcu D, Ardic F, Karabulut N, et al. Hylan G-F 20 efficacy on articular cartilage quality in patients with knee osteoarthritis: clinical and MRI assessment. Clin Rheumatol. 2005;24(4):336-41. [pmid: 15599642].
Dahlberg L, Lohmander LS, Ryd L. Intraarticular injections of hyaluronan in patients with cartilage abnormalities and knee pain. A one-year double-blind, placebo-controlled study. Arthritis Rheum. 1994;37(4):521-8. [pmid: 8147929].
D'Ambrosio E, Casa B, Bompani R, et al. Glucosamine sulphate: a controlled clinical investigation in arthrosis. Pharmatherapeutica. 1981;2(8):504-8. [pmid: 7019929].
Das A Jr, Hammad TA. Efficacy of a combination of FCHG49 glucosamine hydrochloride, TRH122 low molecular weight sodium chondroitin sulfate and manganese ascorbate in the management of knee osteoarthritis. Osteoarthritis Cartilage. 2000;8(5):343-50. [pmid: 10966840].
Davis MA, Ettinger WH, Neuhaus JM, et al. Correlates of knee pain among US adults with and without radiographic knee osteoarthritis. J Rheumatol. 1992;19:1943-49. [pmid: 1294744].
Day B. The indications for arthroscopic debridement for osteoarthritis of the knee. Orthop Clin North Am. Oct. 2005;36(4):413-417. [pmid: 16164946].
Day R, Brooks P, Conaghan PG, et al. A double blind, randomized, multicenter, parallel group study of the effectiveness and tolerance of intraarticular hyaluronan in osteoarthritis of the knee. J Rheumatol. 2004;31(4):775-82. [pmid: 15088306].
Deal CL, Moskowitz RW. Nutraceuticals as therapeutic agents in osteoarthritis. The role of glucosamine, chondroitin sulfate, and collagen hydrolysate. Rheum Dis Clin North Am. May. 1999;25(2):379-395. [pmid: 10356424].
Dervin GF, Stiell IG, Rody K, et al. Effect of arthroscopic debridement for osteoarthritis of the knee on health-related quality of life. J Bone Joint Surg Am. 2003;85-A(1):10-9. [pmid: 12533566].
Dickson J, Hosie G. Double-blind, double-control comparison of viscosupplementation with hylan GF 20 (Synvisc®) against diclofenac and control in knee osteoarthritis. Arthritis Rheum. 1998;41(Suppl 9):S197.
Dickson DJ, Hosie G, English JR. A double-blind, placebo-controlled comparison of hylan G-F 20 against diclofenac in knee osteoarthritis. J Clin Res. 2001;4:41-52.
Dixon AS, Jacoby RK, Berry H, et al. Clinical trial of intra-articular injection of sodium hyaluronate in patients with osteoarthritis of the knee. Curr Med Res Opin. 1988;11(4):205-13. [pmid: 3063436].
Dougados M, Nguyen M, Listrat V, et al. High molecular weight sodium hyaluronate (hyalectin) in osteoarthritis of the knee: a 1 year placebo-controlled trial. Osteoarthritis Cartilage. 1993;1(2):97-103. [pmid: 8886085].
Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259]. [pmcid: 1756728].
Drovanti A, Bignamini AA, Rovati AL. Therapeutic activity of oral glucosamine sulfate in osteoarthrosis: a placebo-controlled double-blind investigation. Clin Ther. 1980;3(4):260-72. [pmid: 7023675].
DuMouchel W. 1994. Hierarchical Bayes linear models for meta-analysis. NISS Technical Report Number 27. Research Triangle Park, NC: National Institute of Statistical Sciences; 1994. Available at www.niss.org/technicalreports/tr27.pdf. Accessed April 2007.
Espallargues M, Pons JM. Efficacy and safety of viscosupplementation with Hylan G-F 20 for the treatment of knee osteoarthritis: a systematic review. Int J Technol Assess Health Care. 2003;19(1):41-56. [pmid: 12701938].
Ewing W, Ewing JW. Arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(21):1717-9. [pmid: 12448429].
Felson DT, Buckwalter J. Debridement and lavage for osteoarthritis of the knee. N Engl J Med. 2002;347(2):132-3. [pmid: 12110742].
Felson DT. Osteoarthritis of the knee. N Engl J Med. 2006;354(8):841-848. [pmid: 16495396].
Formiguera SS, Esteve de Miguel R. Intra-articular hyaluronic acid in the treatment osteoarthritis of the knee: A short term study. Eur J Rheumatol Inflamm. 1995;15(1):33-8.
Forster MC, Straw R. A prospective randomised trial comparing intra-articular Hyalgan injection and arthroscopic washout for knee osteoarthritis. Knee. 2003;10(3):291-3. [pmid: 12893153].
Gidwani S, Fairbank A. The orthopaedic approach to managing osteoarthritis of the knee. BMJ. 2004;329:1220-1224. [pmid: 15550426]. [pmcid: 529367].
Grecomoro G, Martorana U, Di Marco C. Intra-articular treatment with sodium hyaluronate in gonarthrosis: a controlled clinical trial versus placebo. Pharmatherapeutica. 1987;5(2):137-41. [pmid: 3310017].
Greenland S, Schlesselman JJ, Criqui MH. The fallacy of employing standardized regression coefficients and correlations as measures of effect. Am J Epidemiol. 1986;123(2):203-8. [pmid: 3946370].
Guler M, Kuran B, Parlar D, et al. Clinical trial of intra-articular injection of hyaluronic acid in patients with osteoarthritis of the knee. Turkey: X National Rheumatology Congress, October 29–November 3, 1996.
Gunther KP. Surgical approaches for osteoarthritis. Best Pract Res Clin Rheumatol. 2001;15:627-643. [pmid: 11567544].
Hamburger MI, Lakhanpal S, Mooar PA, et al. Intra-articular hyaluronans: a review of product-specific safety profiles. Semin Arthritis Rheum. 2003;32(5):296-309. [pmid: 12701040].
Harris RP, Helfand M, Woolf SH, et al. (Methods Work Group, Third US Preventive Services Task Force.) Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
Harwin SF. Arthroscopic debridement for osteoarthritis of the knee: predictors of patient satisfaction. Arthroscopy. 1999;15(2):142-6. [pmid: 10210070].
Hathcock JN, Shao A. Risk assessment for glucosamine and chondroitin sulfate. Regul Toxicol Pharmacol 2006.
Hauselmann HJ. Nutripharmaceuticals for osteoarthritis. Best Pract Res Clin Rheumatol. 2001;15:595-607. [pmid: 11567542].
Hedeker DR, Gibbons RB. Longitudinal data analysis. New York, NY; John Wiley and Sons: 2006.
Henderson EB, Smith EC, Pegley F, et al. Intra-articular injections of 750 kD hyaluronan in the treatment of osteoarthritis: a randomised single centre double-blind placebo-controlled trial of 91 patients demonstrating lack of efficacy. Ann Rheum Dis. 1994;53(8):529-34. [pmid: 7944639]. [pmcid: 1005394].
Herrero-Beaumont G, Roman JA, Trabado MC, et al. Effects of glucosamine sulfate on 6-month control of knee osteoarthritis symptoms vs placebo and acetaminophen: results from the Glucosamine Unum in Die Efficacy (GUIDE) Trial. Arthritis Rheum. 2005;52(9 suppl):1203. Abstract.
Herrero-Beaumont G, Ivorra JA, et al. Glucosamine sulfate in the treatment of knee osteoarthritis symptoms: a randomized, double-blind, placebo-controlled study using acetaminophen as a side comparator. Arthritis Rheum. 2007;56(2):555-67. [pmid: 17265490].
Hizmetli S, Kocagil S, Kaptanoglu E, et al. The efficacy and safety of intra-articular hyaluronic acid in osteoarthritis of the knee: a prospective, double-blind trial. Unpublished study cited in Bellamy N, Campbell J, Robinson V, et al. Viscosupplementation for the treatment of osteoarthritis of the knee. Cochrane Database Syst Rev 2005;(2):CD005321.
Hochberg MC. Nutritional supplements for knee osteoarthritis - still no resolution. N Engl J Med. 2006;354:858-860. [pmid: 16495399].
Hochberg MC, Altman RD, Brandt KD, et al. Guidelines for the medical management of osteoarthritis. Part I. Osteoarthritis of the hip. Arthritis Rheum. 1995a;38(11):1535-40. [pmid: 7488272].
Hochberg MC, Altman RD, Brandt KD, et al. Guidelines for the medical management of osteoarthritis. Part II. Osteoarthritis of the knee. Arthritis Rheum. 1995b;38(11):1541-6. [pmid: 7488273].
Houpt JB, McMillan R, Paget-Dellio D, et al. Effect of glucosamine hydrochloride (GHcl) in the treatment of pain of osteoarthritis of the knee. J Rheumatol. 1998;25(Suppl 52):8. (abstract M22).
Houpt JB, McMillan R, Wein C, et al. Effect of glucosamine hydrochloride in the treatment of pain of osteoarthritis of the knee. J Rheumatol. 1999;26(11):2423-30. [pmid: 10555905].
Hughes R, Carr A. A randomized, double-blind, placebo-controlled trial of glucosamine sulphate as an analgesic in osteoarthritis of the knee. Rheumatology (Oxford). 2002;41(3):279-84. [pmid: 11934964].
Huskisson EC, Donnelly S. Hyaluronic acid in the treatment of osteoarthritis of the knee. Rheumatology (Oxford). 1999;38(7):602-7. [pmid: 10461471].
Ilahi OA, Reddy J, Ahmad I. Deep venous thrombosis after knee arthroscopy: a meta-analysis. Arthroscopy. 2005;21(6):727-30. [pmid: 15944631].
Institute of Medicine and National Research Council. Prototype monograph on glucosamine. Prepared as an example for the report: Dietary Supplements - A Framework for Evaluating Safety. Washington, DC: National Academies Press;2004. Available at www.iom.edu/Object.File/Master/19/560/Introduction%20and%20Glucosamine%20Prototype%20Monograph.v2.pdf. Accessed December 2006.
Jackson RW, Dieterichs C. The results of arthroscopic lavage and debridement of osteoarthritic knees based on the severity of degeneration: a 4- to 6-year symptomatic follow-up. Arthroscopy. 2003;19(1):13-20. [pmid: 12522398].
Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
Johnson LL. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. Arthroscopy. 2002;18(7):683-7. [pmid: 12240635].
Jordan KM, Arden NK, Doherty M, et al. EULAR recommendations 2003: an evidence based approach to the management of knee osteoarthritis: report of a task force of the Standing Committee for International Clinical Studies Including Therapeutic Trials (ESCISIT). Ann Rheum Dis. 2003;62:1145-1155. [pmid: 14644851]. [pmcid: 1754382].
Jubb RW, Piva S, Beinat L, et al. A one-year, randomised, placebo (saline) controlled clinical trial of 500–730 kDa sodium hyaluronate (Hyalgan) on the radiological change in osteoarthritis of the knee. Int J Clin Pract. 2003;57(6):467-74. [pmid: 12918884].
Kaneto H, Xu G, Song KH, et al. Activation of the hexosamine pathway leads to deterioration of pancreatic beta-cell function through the induction of oxidative stress. J Biol Chem. 2001;276(33):31099-31104. [pmid: 11390407].
Karlsson J, Selin-Sjogren L. A comparison of two hyaluronan drugs and placebo in patients with mild to moderate osteoarthritis of the knee—a controlled, randomised, parallel-design multicenter study. Acta Orthop Scand Suppl. 1999;70(Suppl 287):62.
Karlsson J, Sjogren LS, Lohmander LS. Comparison of two hyaluronan drugs and placebo in patients with knee osteoarthritis. A controlled, randomized, double-blind, parallel-design multicentre study. Rheumatology (Oxford). 2002;41(11):1240-8. [pmid: 12421996].
Kellgren JH, Lawrence JS. Radiological assessment of osteoarthrosis. Ann Rheum Dis. 1957;16:494-502. [pmid: 13498604].
Kemper F, Gebhardt U, Meng T, et al. Tolerability and short-term effectiveness of hylan G-F 20 in 4253 patients with osteoarthritis of the knee in clinical practice. Curr Med Res Opin. 2005;21(8):1261-9. [pmid: 16083536].
Kerzberg EM, Roldan EJ, Castelli G, et al. Combination of glycosaminoglycans and acetylsalicylic acid in knee osteoarthrosis. Scand J Rheumatol. 1987;16(5):377-80. [pmid: 3120308].
Kirwan J. Is there a place for intra-articular hyaluronate in osteoarthritis of the knee?. Knee. 2001;8(2):93-101. [pmid: 11337235].
Kotevoglu N, Iyibozkurt PC, Hiz O, et al. A prospective randomised controlled clinical trial comparing the efficacy of different molecular weight hyaluronan solutions in the treatment of knee osteoarthritis. Rheumatol Int. 2006;26(4):325-30. [pmid: 15959784].
Kraus VB. Pathogenesis and treatment of osteoarthritis. Med Clin North Am. 1997;81(1):85-112. [pmid: 9012756].
Krystallis CT, Kirkos JM, Papavasiliou KA, et al. Arthroscopic debridement of the osteoarthritic knee under local anaesthesia. Acta Orthop Belg. 2004;70(3):260-7. [pmid: 15287406].
Larsen A, Dale K, Eek M. Radiographic evaluation of rheumatoid arthritis and related conditions by standard reference films. Acta Radiol Diagn (Stockh). 1977;18(4):481-91. [pmid: 920239].
Laskin RS, Ohnsorge JA. The role of arthroscopy: beneficial, placebo, or worse?. Orthopedics. 2005;28(9):975-6. [pmid: 16190075].
Lau J, Ioannidis JP, Terrin N, et al. The case of the misleading funnel plot. BMJ. 2006;333(7568):597-600. [pmid: 16974018]. [pmcid: 1570006].
Lawrence RC, Helmick CG, Arnett FC, et al. Estimates of the prevalence of arthritis and selected musculoskeletal disorders in the United States. Arthritis Rheum. 1998;41(5):778-799. [pmid: 9588729].
Leeb BF, Schweitzer H, Montag K, et al. A metaanalysis of chondroitin sulfate in the treatment of osteoarthritis. J Rheumatol. 2000;27(1):205-11. [pmid: 10648040].
Leffler CT, Philippi AF, Leffler SG, et al. Glucosamine, chondroitin, and manganese ascorbate for degenerative joint disease of the knee or low back: a randomized, double-blind, placebo-controlled pilot study. Mil Med. 1999;164(2):85-91. [pmid: 10050562].
Lequesne MG, Mery C, Samson M, et al. Indexes of severity for osteoarthritis of the hip and knee: validation in comparison with other assessment tests. Scand J Rheum 1987;(suppl 65):85–89.
L'Hirondel JL. Klinische doppelblind-studie mit oral verabreichtem chondroitinsulfat gegen placebo bei der tibiofemoralen gonarthrose (125 patienten). Litera Rheumatologica. 1992;14:77-84.
Linschoten NJ, Johnson CA. Arthroscopic debridement of knee joint arthritis: effect of advancing articular degeneration. J South Orthop Assoc. 1997;6(1):25-36. [pmid: 9090622].
Livesley PJ, Doherty M, Needoff M, et al. Arthroscopic lavage of osteoarthritic knees. J Bone Joint Surg Br. 1991;73(6):922-6. [pmid: 1720118].
Lo GH, LaValley M, McAlindon T, et al. Intra-articular hyaluronic acid in treatment of knee osteoarthritis: a meta-analysis. JAMA. 2003;290(23):3115-21. [pmid: 14679274].
Lohmander LS, Dalen N, Englund G, et al. Intra-articular hyaluronan injections in the treatment of osteoarthritis of the knee: a randomised, double blind, placebo controlled multicentre trial. Hyaluronan Multicentre Trial Group. Ann Rheum Dis. 1996;55(7):424-31. [pmid: 8774159]. [pmcid: 1010204].
Lopes Vaz A. Double-blind clinical evaluation of the relative efficacy of ibuprofen and glucosamine sulphate in the management of osteoarthrosis of the knee in out-patients. Curr Med Res Opin. 1982;8(3):145-9. [pmid: 7128187].
Lubowitz JH. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. Arthroscopy. 2002;18(8):950-1. [pmid: 12368798].
Lussier A, Cividino AA, McFarlane CA, et al. Viscosupplementation with hylan for the treatment of osteoarthritis: findings from clinical practice in Canada. J Rheumatol. 1996;23(9):1579-85. [pmid: 8877928].
Maheu E, Bonvarlet J. Acute pseudo-septic arthritis post hyaluronane (HA) intra-articular (IA) injections. Results of a French survey in rheumatology practice. European League Against Rheumatism (EULAR) 2003 Annual Meeting. Lisbon, Portugal. Abstract FRI0240. Available at www.abstracts2view.com/eular/view.php?nu=EULAR03L1_2003FRI0240. Accessed November 2006.
Mandelbaum B, Waddell D. Etiology and pathophysiology of osteoarthritis. Orthopedics. 2005;28(2):s207-s214. [pmid: 15747608].
Manek NJ, Lane NE. Osteoarthritis: current concepts in diagnosis and management. Am Fam Physician. 2000;61(6):1795-804. [pmid: 10750883].
Matheson AJ, Perry CM. Glucosamine: a review of its use in the management of osteoarthritis. Drugs Aging. 2003;20(14):1041-1060. [pmid: 14651444].
Mazieres B, Combe B, Phan Van A, et al. Chondroitin sulfate in osteoarthritis of the knee: a prospective, double blind, placebo controlled multicenter clinical study. J Rheumatol. 2001;28(1):173-81. [pmid: 11196521].
Mazieres B, Hucher M, Zaim M, et al. Effect of chondroitin sulfate in symptomatic knee osteoarthritis: a multicenter, randomized, double-blind, placebo-controlled study. Ann Rheum Dis 2007 Jan 4; [Epub ahead of print].
Mazieres B, Loyau G, Menkes CJ, et al. [Chondroitin sulfate in the treatment of gonarthrosis and coxarthrosis. 5-months result of a multicenter double-blind controlled prospective study using placebo]. Rev Rhum Mal Osteoartic. 1992;59(78):466-72. [pmid: 1485136].
McAlindon T. Why are clinical trials of glucosamine no longer uniformly positive?. Rheum Dis Clin North Am. 2003;29(4):789-801. [pmid: 14603583].
McAlindon T, Formica M, LaValley M, et al. Effectiveness of glucosamine for symptoms of knee osteoarthritis: results from an internet-based randomized double-blind controlled trial. Am J Med. 2004;117(9):643-9. [pmid: 15501201].
McAlindon TE, LaValley MP, Gulin JP, et al. Glucosamine and chondroitin for treatment of osteoarthritis: a systematic quality assessment and meta-analysis. JAMA. 2000;283(11):1469-75. [pmid: 10732937].
McConnell S, Kolopack P, Davis AM. The Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC): a review of its utility and measurement properties. Arthritis Care Res. 2001;45:453-461.
McGinley BJ, Cushner FD, Scott WN. Debridement arthroscopy. 10-year followup. Clin Orthop Relat Res 1999;(367):190–4.
McLaren AC, Blokker CP, Fowler PJ, et al. Arthroscopic debridement of the knee for osteoarthrosis. Can J Surg. 1991;34(6):595-8. [pmid: 1747839].
McQuay HJ, Moore A. Evidenced-based resource for pain relief. NY: Oxford University Press; 1998.
Merchan EC, Galindo E. Arthroscope-guided surgery versus nonoperative treatment for limited degenerative osteoarthritis of the femorotibial joint in patients over 50 years of age: a prospective comparative study. Arthroscopy. 1993;9(6):663-7. [pmid: 8305102].
Michel BA, Stucki G, Frey D, et al. Chondroitins 4 and 6 sulfate in osteoarthritis of the knee: a randomized, controlled trial. Arthritis Rheum. 2005;52(3):779-86. [pmid: 15751094].
Modawal A, Ferrer M, Choi HK, et al. Hyaluronic acid injections relieve knee pain. J Fam Pract. 2005;54(9):758-67. [pmid: 16144589].
Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Lancet. 1999;354:1896-1900. [pmid: 10584742].
Monauni T, Zenti MG, Cretti A, et al. Effects of glucosamine infusion on insulin secretion and insulin action in humans. Diabetes. 2000;49(6):926-35. [pmid: 10866044].
Moreland LW, Arnold WJ, Saway A, et al. Efficacy and safety of intra-articular hylan G-F 20 (Synvisc), a viscoelastic derivative of hyaluronan, in patients with osteoarthritis of the knee. Arthritis Rheum. 1993;36(Suppl 9):165.
Morreale P, Manopulo R, Galati M, et al. Comparison of the antiinflammatory efficacy of chondroitin sulfate and diclofenac sodium in patients with knee osteoarthritis. J Rheumatol. 1996;23(8):1385-91. [pmid: 8856618].
Moseley JB, O'Malley K, Petersen NJ, et al. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. 2002;347(2):81-8. [pmid: 12110735].
Muller-Fassbender H, Bach GL, Haase W, et al. Glucosamine sulfate compared to ibuprofen in osteoarthritis of the knee. Osteoarthritis Cartilage. 1994;2(1):61-9. [pmid: 11548225].
Muniyappa R, Karne RJ, Hall G, et al. Oral glucosamine for 6 weeks at standard doses does not cause or worsen insulin resistance or endothelial dysfunction in lean or obese subjects. Diabetes. 2006;55(11):3142-50. [pmid: 17065354].
Neustadt D, Wade J, Gimbel J, et al. Clinical effects of intra-articular high molecular weight hyaluronan (Orthovisc®) in osteoarthritis of the knee. Arthritis Rheum. 2004;50(Suppl 9):S144. (Abstract #238).
Neustadt DH. Intraarticular steroid therapy. In: Osteoarthritis: diagnosis and medical/surgical management. RW Moskowitz, et al., eds. Philadelphia;WB Sanders, 1992.
Neustadt DH, Caldwell JR, Burnette MC, et al. Intra-articular high molecular weight hyaluronan (Orthovisc(R)) is effective in the treatment of pain of knee osteoarthritis. Ann Rheum Dis. 2005;64(Suppl III):493. (Abstract #SAT0265).
Noack W, Fischer M, Forster KK, et al. Glucosamine sulfate in osteoarthritis of the knee. Osteoarthritis Cartilage. 1994;2(1):51-9. [pmid: 11548224].
Ogilvie-Harris DJ, Fitsialos DP. Arthroscopic management of the degenerative knee. Arthroscopy. 1991;7(2):151-7. [pmid: 2069626].
O'Malley KJ, Suarez-Almazor M, Aniol J, et al. Joint-specific multidimensional assessment of pain (J-MAP): factor structure, reliability, validity, and responsiveness in patients with knee osteoarthritis. J Rheumatol. 2003;30(3):534-43. [pmid: 12610814].
Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-1278. [pmid: 1834807].
Oxman AD, Guyatt GH, Singer J, et al. Agreement among reviewers of review articles. J Clin Epidemiol. 1991;44(1):91-8. [pmid: 1824710].
Pavelka K, Bucsi L, Manopulo R. Double-blind, dose effect study of oral CS 4 & 6 1200 mg, 800 mg, 200 mg against placebo in the treatment of femorotibial osteoarthritis. EULAR Rheumatol Litera. 1998;27(Suppl 2):63.
Pavelka K, Gatterova J, Olejarova M, et al. Glucosamine sulfate use and delay of progression of knee osteoarthritis: a 3-year, randomized, placebo-controlled, double-blind study. Arch Intern Med. 2002;162(18):2113-23. [pmid: 12374520].
Pendleton A, Arden N, Dougados M, et al. EULAR recommendations for the management of knee osteoarthritis: report of a task force of the Standing Committee for International Clinical Studies Including Therapeutic Trials (ESCISIT). Ann Rheum Dis. 2000;59:936-44. [pmid: 11087696]. [pmcid: 1753053].
Petrella RJ, DiSilvestro MD, Hildebrand C. Effects of hyaluronate sodium on pain and physical functioning in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled clinical trial. Arch Intern Med. 2002;162(3):292-8. [pmid: 11822921].
Petrella RJ, Petrella M. A prospective, randomized, double-blind, placebo controlled study to evaluate the efficacy of intraarticular hyaluronic acid for osteoarthritis of the knee. J Rheumatol. 2006;33(5):951-6. [pmid: 16652426].
Peyron JQ. Intraarticular hyaluronan injections in the treatment of osteoarthritis: state-of-the-art review. J Rheumatol. 1993;20(suppl 39):10-15.
Pham T, Le Henanff A, Ravaud P, et al. Evaluation of the symptomatic and structural efficacy of a new hyaluronic acid compound, NRD101, in comparison with diacerein and placebo in a 1 year randomised controlled study in symptomatic knee osteoarthritis. Ann Rheum Dis. 2004;63(12):1611-7. [pmid: 15331394]. [pmcid: 1754857].
Pham T, van der Heijde D, Altman RD, et al. OMERACT-OARSI initiative: Osteoarthritis Research Society International set of responder criteria for osteoarthritis clinical trials revisited. Osteoarthritis Cartilage. 2004;12(5):389-99. [pmid: 15094138].
Poehling GG. Degenerative arthritis arthroscopy and research. Arthroscopy. 2002;18(7):683-7. [pmid: 12209424].
Poolsup N, Suthisisang C, Channark P, et al. Glucosamine long-term treatment and the progression of knee osteoarthritis: systematic review of randomized controlled trials. Ann Pharmacother. 2005;39(6):1080-7. [pmid: 15855241].
Pouwels MJ, Jacobs JR, Span PN, et al. Short-term glucosamine infusion does not affect insulin sensitivity in humans. Clin Endocrinol Metab. 2001;86(5):2099-103.
Puhl W, Bernau A, Greiling H, et al. Intra-articular sodium hyaluronate in osteoarthritis of the knee: a multicenter, double-blind study. Osteoarthritis Cartilage. 1993;1(4):233-41. [pmid: 15449510].
Pujalte JM, Llavore EP, Ylescupidez FR. Double-blind clinical evaluation of oral glucosamine sulphate in the basic treatment of osteoarthrosis. Curr Med Res Opin. 1980;7(2):110-14. [pmid: 7002479].
Qiu GX, Gao SN, Giacovelli G, et al. Efficacy and safety of glucosamine sulfate versus ibuprofen in patients with knee osteoarthritis. Arzneimittelforschung. 1998;48(5):469-74. [pmid: 9638313].
Reginster JY, Deroisy R, Rovati LC, et al. Long-term effects of glucosamine sulphate on osteoarthritis progression: a randomised, placebo-controlled clinical trial. Lancet. 2001;357(9252):251-6. [pmid: 11214126].
Reichelt A, Forster KK, Fischer M, et al. Efficacy and safety of intramuscular glucosamine sulfate in osteoarthritis of the knee. A randomised, placebo-controlled, double-blind study. Arzneimittelforschung. 1994;44(1):75-80. [pmid: 8135881].
Richy F, Bruyere O, Ethgen O, et al. Structural and symptomatic efficacy of glucosamine and chondroitin in knee osteoarthritis: a comprehensive meta-analysis. Arch Intern Med. 2003;163(13):1514-22. [pmid: 12860572].
Rindone JP, Hiller D, Collacott E, et al. Randomized, controlled trial of glucosamine for treating osteoarthritis of the knee. West J Med. 2000;172(2):91-4. [pmid: 10693368]. [pmcid: 1070762].
Rolf CG, Engstrom B, Ohrvik J, et al. A comparative study of the efficacy and safety of hyaluronan viscosupplements and placebo in patients with symptomatic and arthroscopy-verified cartilage pathology. J Clin Res. 2005;8(1532):15-32.
Rothman K, Greenland S. Modern epidemiology, 2nd Ed. Philadelphia: Lippincott-Raven; 1998.
Rovati LC. The clinical profile of glucosamine sulfate as a selective symptom modifying drug in osteoarthritis: current data and perspectives. Osteoarthritis Cartilage. 1997;5(Suppl A):72.
Rovetta G. Galactosaminoglycuronoglycan sulfate (matrix) in therapy of tibiofibular osteoarthritis of the knee. Drugs Exp Clin Res. 1991;17(1):53-7. [pmid: 1914837].
Russell IJ, Michalek JE, Lawrence VA, et al. A randomized, placebo (PL) and no-intervention (NI) controlled trial of intra-articular (IA) 1 percent sodium hyaluronate (HA) in the treatment of knee osteoarthritis (OA). Arthritis Rheum. 1992;35(Suppl):S132-9.
Sacks HS, Reitman D, Pagano D, et al. Meta-analysis: An update. Mt Sinai J Med. 1996;63(34):216-24. [pmid: 8692168].
Salaffi F, Carotti M, Grassi W. Health-related quality of life in patients with hip or knee osteoarthritis: comparison of generic and disease-specific instruments. Clin Rheumatol. 2005;24(1):29-37. [pmid: 15674656].
Scale D, Wobig M, Wolpert W. Viscosupplementation of osteoarthritic knees with hylan: a treatment schedule study. Curr Ther Res Clin Exp. 1994;55(3):220-32.
Scroggie DA, Albright A, Harris MD. The effect of glucosamine-chondroitin supplementation on glycosylated hemoglobin levels in patients with type 2 diabetes mellitus: a placebo-controlled, double-blinded, randomized clinical trial. Arch Intern Med. 2003;163(13):1587-90. [pmid: 12860582].
Senn S. Statistical issues in drug development. NY: John Wiley and Sons; 1997.
Sezgin M, Demirel AC, Karaca C, et al. Does hyaluronan affect inflammatory cytokines in knee osteoarthritis?. Rheumatol Int. 2005;25(4):264-9. [pmid: 14999424].
Shannon FJ, Devitt AT, Poynton AR, et al. Short-term benefit of arthroscopic washout in degenerative arthritis of the knee. Int Orthop. 2001;25(4):242-5. [pmid: 11561500].
Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989]. [pmcid: 1810543].
Shichikawa K, Igarashi M, Sugawara S, et al. Clinical evaluation of high molecular weight sodium hyaluronate (SPH) on osteoarthritis of the knee—a multi-center well controlled comparative study. Jpn J Clin Pharmacol Therapeut. 1983a;14(3):545-58.
Shichikawa K, Maeda A, Ogawa N. [Clinical evaluation of sodium hyaluronate in the treatment of osteoarthritis of the knee]. Ryumachi. 1983b;23(4):280-90. [pmid: 6364389].
Sprague NF 3rd. Arthroscopic debridement for degenerative knee joint disease. Clin Orthop Relat Res 1981;(160):118–23.
Sterne JA, Egger M. Funnel plots for detecting bias in meta-analysis: guidelines on choice of axis. J Clin Epidemiol. 2001;54(10):1046-55. [pmid: 11576817].
Strand V, Conaghan PG, Lohmander LS, et al. An integrated analysis of five double-blind, randomized controlled trials evaluating the safety and efficacy of a hyaluronan product for intra-articular injection in osteoarthritis of the knee. Osteoarthritis Cartilage. 2006;14:859. [pmid: 16626978].
Stumpf JL, Lin SW. Effect of glucosamine on glucose control. Ann Pharmacother. 2006;40(4):694-8. [pmid: 16569816].
Tamir E, Robinson D, Koren R, et al. Intra-articular hyaluronan injections for the treatment of osteoarthritis of the knee: a randomized, double blind, placebo controlled study. Clin Exp Rheumatol. 2001;19(3):265-70. [pmid: 11407078].
Tannis AJ, Barban J, Conquer JA. Effect of glucosamine supplementation on fasting and non-fasting plasma glucose and serum insulin concentrations in healthy individuals. Osteoarthritis Cartilage. 2004;12(6):506-11. [pmid: 15135147].
Timoney JM, Kneisl JS, Barrack RL, et al. Arthroscopy update #6. Arthroscopy in the osteoarthritic knee. Long-term follow-up. Orthop Rev 1990;19(4):371–3, 376–9.
Towheed TE, Maxwell L, Anastassiades TP, et al. Glucosamine therapy for treating osteoarthritis. Cochrane Database Syst Rev 2005;(2):CD002946.
Tsai CL, Chang CC, Chen SC, et al. Treatment of knee osteoarthritis in Asian population with an intra-articular hyaluronan of MW500–730 KDa. Osteoarthritis Cartilage. 2003;11(Suppl A):119.
Tubach F, Wells GA, Ravaud P, et al. Minimal clinically important difference, low disease activity state, and patient acceptable symptom state: methodological issues. J Rheumatol. 2005;32(10):2025-9. [pmid: 16206363].
Uebelhart D, Malaise M, Marcolongo R, et al. Intermittent treatment of knee osteoarthritis with oral chondroitin sulfate: a one-year, randomized, double-blind, multicenter study versus placebo. Osteoarthritis Cartilage. 2004;12(4):269-76. [pmid: 15023378].
Uebelhart D, Thonar EJ, Delmas PD, et al. Effects of oral chondroitin sulfate on the progression of knee osteoarthritis: a pilot study. Osteoarthritis Cartilage. 1998;6(Suppl A):39-46. [pmid: 9743819].
Usha PR, Naidu MUR. Randomised, double-blind, parallel, placebo-controlled study of oral glucosamine, methylsulfonylmethane and their combination in osteoarthritis. Clin Drug Invest. 2004;24(6):353-63.
Vajaradul Y. Double-blind clinical evaluation of intra-articular glucosamine in outpatients with gonarthrosis. Clin Ther. 1981;3(5):336-43. [pmid: 7008939].
Vajranetra P. Clinical trial of glucosamine compounds for osteoarthrosis of knee joints. J Med Assoc Thai. 1984;67(7):409-18. [pmid: 6392462].
van Belle G. Statistical rules of thumb. NY: Wiley; 2002.
Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med. 2007;26(1):37-52. [pmid: 16463355].
Waddell DD. The tolerability of viscosupplementation: low incidence and clinical management of local adverse events. Curr Med Res Opin. 2003;19(7):575-80. [pmid: 14626291].
Wai EK, Kreder HJ, Williams JI. Arthroscopic debridement of the knee for osteoarthritis in patients fifty years of age or older: utilization and outcomes in the Province of Ontario. J Bone Joint Surg Am. 2002;84-A(1):17-22. [pmid: 11792774].
Wang CJ, Chen HS, Huang TW, et al. Outcome of surgical reconstruction for posterior cruciate and posterolateral instabilities of the knee. Injury. 2002;33(9):815-21. [pmid: 12379393].
Weinstein JN, Tosteson TD, Lurie JD, et al. Surgical vs nonoperative treatment for lumbar disk herniation: the Spine Patient Outcomes Research Trial (SPORT): a randomized trial. JAMA. Nov 22. 2006;296(20):2441-50. [pmid: 17119140]. [pmcid: 2553805].
West S, King V, Carey TS, et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report/Technology Assessment No. 47 (Prepared by the Research Triangle Institute-University of North Carolina Evidence-based Practice Center under Contract No. 290-97-0011). AHRQ Publication No. 02-E016. Rockville, MD: Agency for Healthcare Research and Quality. April 2002.
Wobig M, Dickhut A, Maier R, et al. Viscosupplementation with hylan G-F 20: a 26-week controlled trial of efficacy and safety in the osteoarthritic knee. Clin Ther. 1998;20(3):410-23. [pmid: 9663358].
Wobig M, Bach G, Beks P, et al. The role of elastoviscosity in the efficacy of viscosupplementation for osteoarthritis of the knee: a comparison of hylan G-F 20 and a lower-molecular-weight hyaluronan. Clin Ther. 1999;21(9):1549-62. [pmid: 10509850].
Wray NP, Moseley JB, O'Malley K. Arthroscopic treatment of osteoarthritis of the knee. J Bone Joint Surg Am. 2003;85-A(2):381. [pmid: 12571321].
Wu JJ, Shih LY, Hsu HC, et al. The double-blind test of sodium hyaluronate (ARTZ) on osteoarthritis knee. Zhonghua Yi Xue Za Zhi (Taipei). 1997;59(2):99-106. [pmid: 9175299].
Yang SS, Nisonson B. Arthroscopic surgery of the knee in the geriatric patient. Clin Orthop Relat Res 1995;(316):50–8.
Yoshikawa H, Tajiri Y, Sako Y, et al. Glucosamine-induced beta-cell dysfunction: a possible involvement of glucokinase or glucose-transporter type 2. Pancreas. 2002;24(3):228-34. [pmid: 11893929].
Zenk JL, Helmer TR, Kuskowski MA. The effects of milk protein concentrate on the symptoms of osteoarthritis in adults: an exploratory, randomized, double-blind, placebo-controlled trial. Curr Ther Res. 2002;63(7):430-42.